# Bibliography

Abby SL, Harris IM, Harris KM. Homocysteine and cardiovascular disease. J Am Board Fam Prac. 1998;11:391-398.
Abrams DB, Boutwell WB, Grizzle J, et al. Cancer control at the workplace: The Working Well Trial. Prev Med. 1994;23:15-27. [pmid: 8016028].
AbuSabha R, Achterberg C. Review of self-efficacy and locus of control for nutrition and health-related behavior. J Am Diet Assoc. 1997;97:1122-1132. [pmid: 9336559].
AbuSabha R, Peacock J, Achterberg C. How to make nutrition education more meaningful through facilitated group discussions. J Am Diet Assoc. 1999;99:72-76. [pmid: 9917735].
Achterberg C. Factors that influence learner readiness. J Am Diet Assoc. 1988;88:1426-1428. [pmid: 3183263].
Achterberg C, McDonnell E, Bagby R. How to put the Food Guide Pyramid into practice. J Am Diet Assoc. 1994;94:1030-1035. [pmid: 8071485].
Achterberg CL. Qualitative research: What do we know about teaching good nutritional habits?. J Nutr. 1994;124(9 suppl):808S-1812S.
Adams M, Kerby IJ, Rocker I, et al. A comparison of the toxicity and efficacy of cisplatin and carboplatin in advanced ovarian cancer. The Swons Gynaecological Cancer Group. Acta Oncologica. 1989;28:57-60. [pmid: 2650722].
Adeyanju M, Creswell WH Jr. The relationship among attitudes, behaviors, and biomedical measures of adolescents 'at risk' for cardiovascular disease. J School Health. 1987;57:326-331. [pmid: 3695417].
Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-1511. [pmid: 9314625].
Airhihenbuwa CO, Kumanyika S, Agurs TD, et al. Cultural aspects of African American eating patterns. Ethnicity & Health. 1996;1:245-260. [pmid: 9395569].
Aish A. A comparison of female and male cardiac patients' response to nursing care promoting nutritional self-care. Can J Cardiovasc Nurs. 1996;7:4-13. [pmid: 9136305].
Alberg AJ, Visvanathan K, Helzlsouer KJ. Epidemiology, prevention, and early detection of breast cancer. Curr Opinion in Oncol. 1998;10:492-497.
Alberts DS, Einspahr J, Ritenbaugh C, et al. The effect of wheat bran fiber and calcium supplementation on rectal mucosal proliferation rates in patients with resected adenomatous colorectal polyps. Cancer Epidemiol, Biomarkers Prev. 1997;6:161-169. [pmid: 9138658].
Alberts DS, Lipkin M, Levin B. Genetic screening for colorectal cancer and intervention. Int J Cancer. 1996;69:62-63. [pmid: 8600065].
Alberts DS, Martinez ME, Roe DJ, et al. Lack of effect of a high-fiber cereal supplement on the recurrence of colorectal adenomas. N Engl J Med. 2000;342:1156-1162. [pmid: 10770980].
Alberts DS, Ritenbaugh C, Story JA, et al. Randomized, double-blinded, placebo-controlled study of effect of wheat bran fiber and calcium on fecal bile acids in patients with resected adenomatous colon polyps. J Natl Cancer Inst. 1996;88:81-92. [pmid: 8537982].
Albright CL. Nutritional epidemiology: Methods and innovations used in a central European community-based program. Nutrition. 1996;12:386-387. [pmid: 8875530].
Alexander JW. Immunoenhancement via enteral nutrition. Arch Surg. 1993;128:1242-1245. [pmid: 7694565].
Allen JC, Bloom J, Ertel I, et al. Brain tumors in children: Current cooperative and institutional chemotherapy trials in newly diagnosed and recurrent disease. Seminars in Oncol. 1986;13:110-122. [pmid: 3513315].
American Cancer Society 1996 Advisory Committee on Diet, Nutrition, and Cancer Prevention. Guidelines on diet, nutrition, and cancer prevention: Reducing the risk of cancer with healthy food choices and physical activity. CA-A Cancer J Clinicians. 1996;25:325-341.
Ammerman AS, deVellis BM, Haines PS, et al. Nutrition education for cardiovascular disease prevention among low income populations-description and pilot evaluation of a physician-based model. Patient Educ Counsel. 1992;19:5-18.
Ammerman AS, deVellis RF, Carey TS, et al. Physician-based diet counseling for cholesterol reduction: Current practices, determinants, and strategies for improvement. Prev Med. 1993;22:96-109. [pmid: 8475015].
Amos A, Currie CE, Hunt SM. A comparison of the consistency of self-reported behavioural change within a study sample: Postal versus home interviews. Health Educ Res. 1991;6:479-486. [pmid: 10148704].
Anderson G, Cummings S, Freedman LS, et al. Design of the Women's Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19:61-109. [pmid: 9492970].
Anderson J, Dusenbury L. Worksite cholesterol and nutrition: An intervention project in Colorado. AAOHN J. 1999;47:99-106. [pmid: 10347395].
Anderson JW. Diet, lipids and cardiovascular disease in women. J Am Coll Nutr. 1993;12:433-437. [pmid: 8409106].
Anderson JW, Gustafson NJ. Adherence to high-carbohydrate, high-fiber diets. Diabetes Educator. 1989;15:429-434. [pmid: 2550195].
Anderson KM, Evans A, Kellen JA. Unimpaired development of DMBA-induced mammary tumors in rats treated with poly(I)-poly(C). Res Commun Chem Pathol Pharmacol. 1972;4:193-202. [pmid: 4672033].
Andrykowski MA, Otis ML. Development of learned food aversions in humans: Investigation in a 'natural laboratory' of cancer chemotherapy. Appetite. 1990;14:145-158. [pmid: 2337341].
Anonymous. Mr. Fit versus heart attacks. Hospitals. 1974;48.
Anonymous. Effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. Diabetes. 1982;31 (5 suppl):1-81.
Anonymous. Guidelines for the treatment of mild hypertension: Memorandum from a WHO/ISH meeting. Hypertension. 1983;5:394-397. [pmid: 6840825].
Anonymous. The Oslo Diet and Exercise Study (ODES): Design and objectives. Control Clin Trials. 1993;14:229-243. [pmid: 8339552].
Anonymous. Position of the American Diet Association: Vitamin and mineral supplementation. J Am Diet Assoc. 1996;96:73-77. [pmid: 8537577].
Anonymous. A dietary intervention trial for nutritional management of cardiovascular risk factors. Nutr Rev. 1997;55:54-56. [pmid: 9155219].
Anonymous. Hyperlipidemia management in patients with cardiovascular and cerebrovascular disease. J Florida Med Assoc. 1998;85:26-28.
Anonymous. Study on primary prevention of coronary heart disease with lovastatin. Pharmazeutische Zeitung. 1998;143(1-2).
Appel LJ, Espeland M, Whelton PK, et al. Trial of Nonpharmacologic Intervention in the Elderly (TONE). Design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5:119-129. [pmid: 7795830].
Appel LJ, Hebert PR, Cohen JD, et al. Baseline characteristics of participants in phase II of the Trials of Hypertension Prevention (TOHP II). Trials of Hypertension Prevention Collaborative Research Group. Ann Epidemiol. 1995;5:149-155. [pmid: 7795833].
Applegate WB, Miller ST, Elam JT, et al. Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152:1162-1166. [pmid: 1599343].
Arseneau DL, Mason AC, Wood OB, et al. A comparison of learning activity packages and classroom instruction for diet management of patients with non-insulin-dependent diabetes mellitus. Diabetes Educator. 1994;20:509-514. [pmid: 7851264].
Arthur R. Cholesterol lowering benefits diabetics. Br J Cardiol. 1997;4:181-182.
Ashutosh K, Methrotra K, Fragale-Jackson J. Effects of sustained weight loss and exercise on aerobic fitness in obese women. J Sports Med Phys Fitness. 1997;37:252-257. [pmid: 9509823].
Astrup A, Toubro S, Raben A, et al. The role of low-fat diets and fat substitutes in body weight management: What have we learned from clinical studies?. J Am Diet Assoc. 1997;97(7 suppl):S82-S87. [pmid: 9216575].
Atwood JR, Aickin M, Giordano L, et al. The effectiveness of adherence intervention in a colon cancer prevention field trial. Prev Med. 1992;21:637-653. [pmid: 1332022].
Aubin M, Godin G, Vezina L, et al. Hypercholesterolemia screening. Does knowledge of blood cholesterol level affect dietary fat intake?. Can Fam Physician. 1998;44:1289-1297. [pmid: 9640523].
Auld GW, Achterberg C, Durrwachter J, et al. Gender differences in adults' knowledge about fat and cholesterol. J Am Diet Assoc. 1991;91:1391-1397. [pmid: 1939976].
Backovic D, Marinkovic J, Jorga J, et al. Environmental factors, health-related habits, and serum selenium levels in cancer patients and healthy controls. Biol Trace Element Res. 1999;67:55-62.
Bakx JC, Stafleu A, van Staveren WA, et al. Long-term effect of nutritional counseling: A study in family medicine. Am J Clin Nutr. 1997;65(6 suppl):1946S-1950S. [pmid: 9174500].
Bal' LV, Shugaeva EN, Deev AA, et al. Results of a three-year trial of arterial hypertension prevention in a population of children aged 11-15 years by overweight control. Cor Et Vasa. 1990;32:448-456. [pmid: 2085976].
Balady GJ, Fletcher BJ, Froelicher ES, et al. Cardiac rehabilitation programs: A statement for healthcare professionals from the American Heart Association. Circulation. 1994;90:1602-1610. [pmid: 8087975].
Banks WA, Corrigan SA, West JA, et al. Psychologic profiles as predictors of success in a cardiovascular risk factors life-style intervention program. South Med J. 1996;89:971-976. [pmid: 8865789].
Baranowski T, Cullen KW, Basen-Engquist K, et al. Transitions out of high school: Time of increased cancer risk?. Prev Med. 1997;26(5 Pt 1):694-703. [pmid: 9327479].
Baranowski T, Davis M, Resnicow K, et al. Gimme 5 fruit, juice, and vegetables for fun and health: Outcome evaluation. Health Educ Behav. 2000;27:96-111. [pmid: 10709795].
Baranowski T, Dworkin R, Henske JC, et al. The accuracy of children's self-reports of diet: Family Health Project. J Am Diet Assoc. 1986;86:1381-1385. [pmid: 3760429].
Baranowski T, Hearn MD, Gochman DS et al. (Ed.), Relevance for professionals and issues for the future. Handbook of health behavior research. 1997;4:303-323. [pmcid: 151281].
Baranowski T, Henske J, Simons-Morton B, et al. Dietary change for cardiovascular disease prevention among Black-American families. Health Educ Res. 1990;5:433-433.
Baranowski T, Nader PR, Dunn K, et al. Family self-help: Promoting changes in health behavior. J Commun. 1982;32:161-172.
Baranowski T, Simons-Morton BG. Dietary and physical activity assessment in school-aged children: Measurement issues. J School Health. 1991;61:195-197. [pmid: 1943040].
Baranowski T, Smith M, Hearn MD, et al. Patterns in children's fruit and vegetable consumption by meal and day of the week. J Am Coll Nutr. 1997;16:216-223. [pmid: 9176827].
Baron JA, Gleason R, Crowe B, et al. Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Prac. 1990;40(333):137-141.
Baron JA, Tosteson TD, Wargovich MJ, et al. Calcium supplementation and rectal mucosal proliferation: A randomized controlled trial. J Natl Cancer Inst. 1995;87:1303-1307. [pmid: 7658482].
Bauer RL, Heller RF, Challah S. United Kingdom Heart Disease Prevention Project: 12-year follow-up of risk factors. Am J Epidemiol. 1985;121:563-569. [pmid: 4014145].
Baxter AP, Milner PC, Hawkins S, et al. The impact of heart health promotion on coronary heart disease lifestyle risk factors in schoolchildren: Lessons learnt from a community-based project. Public Health. 1997;111:231-237. [pmid: 9242036].
Beckmann SL, Os I, Kjeldsen SE, et al. Effect of dietary counselling on blood pressure and arterial plasma catecholamines in primary hypertension. Am J Hyperten. 1995;8:704-711. [pmid: 7546496].
Becque MD, Katch VL, Rocchini AP, et al. Coronary risk incidence of obese adolescents: Reduction by exercise plus diet intervention. Pediatrics. 1988;81:605-612. [pmid: 3357722].
Berenson GS, Voors AW, Webber LS, et al. A model of intervention for prevention of early essential hypertension in the 1980s. Hypertension. 1983;5:41-54. [pmid: 6848468].
Berenson M, Groshen S, Miller H, et al. Subject-reported compliance in a chemoprevention trial for familial adenomatous polyposis. J Behav Med. 1989;12:233-247. [pmid: 2561292].
Beresford SAA, Curry SJ, Kristal AR, et al. A dietary intervention in primary care practice: The eating patterns study. Am J Public Health. 1997;87:610-616. [pmid: 9146440].
Beresford SAA, Farmer EMZ, Feingold L, et al. Evaluation of a self-help dietary intervention in a primary care setting. Am J Public Health. 1992;82:79-84. [pmid: 1311152].
Bernstein M, Morabia A, Costanza MC, et al. Nutritional balance of the diet of the adult residents of Geneva [in French]. Sozial-Und Praventivmedizin. 1994;39:333-344. [pmid: 7817623].
Bernstein M, Sloutskis D, Kumanyika S, et al. Data-based approach for developing a physical activity frequency questionnaire [review]. Am J Epidemiol. 1998;147:147-154. [pmid: 9457004].
Betteridge DJ. Lipid management: Past, present, and future. Br J Clin Prac. 1994;48(77 suppl):1-10.
Billings J, Zeitel L, Lukomnik J, et al. Impact of socioeconomic status on hospital use in New York City. Health Affairs. 1993;12:162-173.
Bingham SA. Dietary assessments in the European prospective study of diet and cancer (EPIC). Eur J Cancer Prev. 1997;6:118-124. [pmid: 9237058].
Biuiatti E. The role of chemoprevention in cancer control. Salud publica de Mexico. 1997;39:310-317. [pmid: 9337563].
Bjartveit K, Foss OP, Gjervig T, et al. The cardiovascular disease study in Norwegian counties. Background and organization. Acta Medica Scandinavica - Supplementum. 1979;634:1-70. [pmid: 293122].
Bjoerkelund C, Bengtsson C. Changing lifestyle: Who benefits and how? Prevention in primary health care within the female population in a Swedish community. Behav Change. 11:145-152.
Bjorkelund C, Bengtsson C. Feasibility of a primary health care programme aiming at reducing cardiovascular and cerebrovascular risk factors among women in a Swedish community, Stromstad. Scand J Primary Health Care. 1991;9:89-95.
Blanke K, Stanek K, Stacy RD. Comparison of the success of nutrition education to lower dietary cholesterol and fat with and without spouse support for individuals with elevated blood cholesterol. Health Values. 14:33-37.
Block G. Health Habits and History Questionnaire: Diet History and Other Risk Factors. Bethesda, MD: National Cancer Institute, 1988.
Bloomfield S, Calder JE, Chisholm V, et al. A project in diabetes education for children. Diabetic Med. 1990;7:137-142. [pmid: 2137754].
Blot WJ, Li JY, Taylor PR, et al. Nutrition intervention trials in Linxian, China: Supplementation with specific vitamin/mineral combinations, cancer incidence, and disease-specific mortality in the general population. J Natl Cancer Inst. 1993;85:1483-1492. [pmid: 8360931].
Blot WJ, Li JY, Taylor PR, et al. The Linxian trials: Mortality rates by vitamin-mineral intervention group. Am J Clin Nutr. 1995;62(6 suppl):1424S-1426S. [pmid: 7495242].
Blumberg J, Block G. The Alpha-Tocopherol, Beta-Carotene cancer prevention study in Finland. Nutr Reviews. 1994;52:242-245.
Blumenthal JA, Levenson RM. Behavioral approaches to secondary prevention of coronary heart disease. Circ. 1987;76(1 Pt 2):I130-I137.
Blumenthal JA, Siegel WC, Appelbaum M. Failure of exercise to reduce blood pressure in patients with mild hypertension. Results of a randomized controlled trial. JAMA. 1991;266:2098-2104. [pmid: 1920698].
Bock BC, Marcus BH, Rossi JS, et al. Motivational readiness for change: Diet, exercise, and smoking. Am J Health Behav. 1998;22(4):248-258.
Boehm S, Schlenk EA, Funnell MM, et al. Predictors of adherence to nutrition recommendations in people with non-insulin-dependent diabetes mellitus. Diabetes Educator. 1997;23:157-165. [pmid: 9155314].
Boehringer-Mannheim Diagnostics Division. Reflotron Cholesterol Screening Daily Operation Manual. Indianapolis, IN: Boehringer Mannheim, 1985.
Borghi L, Meschi T, Guerra A, et al. Randomized prospective study of a nonthiazide diuretic, indapamide, in preventing calcium stone recurrences. J Cardiovasc Pharmacol. 1993;22(6 suppl):S78-S86. [pmid: 7508066].
Borody WL, Brown TE, Boroditsky RS. Dietary fat and calcium intakes of menopausal women. Menopause. 1998;5:230-235. [pmid: 9872490].
Bostick RM, Fosdick L, Wood JR, et al. Calcium and colorectal epithelial cell proliferation in sporadic adenoma patients: A randomized, double-blinded, placebo-controlled clinical trial. J Natl Cancer Inst. 1995;87:1307-1315. [pmid: 7658483].
Bovbjerg VE, McCann BS, Brief DJ, et al. Spouse support and long-term adherence to lipid-lowering diets. Am J Epidemiol. 1995;141:451-460. [pmid: 7879789].
Bowen DJ, Fries E, Hopp HP. Effects of dietary fat feedback on behavioral and psychological variables. J Behav Med. 1994;17:589-604. [pmid: 7739032].
Bowen DJ, Meischke H, Tomoyasu N. Preliminary evaluation of the processes of changing to a low-fat diet. Health Educ Res. 1994;9:85-94.
Boyd NF, Cousins M, Kriukov V. A randomized controlled trial of dietary fat reduction: The retention of subjects and characteristics of drop outs. J Clin Epidemiol. 1992;45:31-38. [pmid: 1738009].
Boyd NF, Lockwood GA, Greenberg CV, et al. Effects of a low-fat high-carbohydrate diet on plasma sex hormones in premenopausal women: Results from a randomized controlled trial. Br J Cancer. 1997;76:127-135. [pmid: 9218745].
Boyd NF, Martin LJ, Beaton M, et al. Long-term effects of participation in a randomized trial of a low-fat, high-carbohydrate diet. Cancer Epidemiol, Biomarkers Prev. 1996;5:217-222. [pmid: 8833622].
Boyle P. Progress in preventing death from colorectal cancer. Br J Cancer. 1995;72:528-530. [pmid: 7669556].
Bozigian HP, Pritchard JF, Gooding AE, et al. Ondansetron absorption in adults: Effect of dosage form, food, and antacids. J Pharm Sci. 1994;83:1011-1013. [pmid: 7965657].
Bozzetti F, Biganzoli L, Gavazzi C, et al. Glutamine supplementation in cancer patients receiving chemotherapy: A double-blind randomized study. Nutrition. 1997;13(7-8):748-751. [pmid: 9263281].
Braga M, Costantini E, Di Francesco A, et al. Impact of thymopentin on the incidence and severity of postoperative infection: A randomized controlled trial. Br J Surg. 1994;81:205-208. [pmid: 8156337].
Brennan AJ. Health and fitness boom moves into corporate America. Occup Health & Safety. 1985;54:38-40, 42-45.
Breslow NE, Norkool PA, Olshan A, et al. Second malignant neoplasms in survivors of Wilms' tumor: A report from the National Wilms' Tumor Study. J Natl Cancer Inst. 1988;80:592-595. [pmid: 2836600].
Brownell KD, Cohen LR. Adherence to dietary regimens: Components of effective interventions. Behav Med. 1995;20(4):155-164. [pmid: 7620227].
Bruera E, Macmillan K, Kuehn N, et al. A controlled trial of megestrol acetate on appetite, caloric intake, nutritional status, and other symptoms in patients with advanced cancer. Cancer. 1990;66:1279-1282. [pmid: 2205358].
Brug J, Glanz K, van Assema P, et al. The impact of computer-tailored feedback and iterative feedback on fat, fruit, and vegetable intake. Health Educ Behav. 1998;25:517-531. [pmid: 9690108].
Brug J, Hospers HJ, Kok G. Differences in psychosocial factors and fat consumption between stages of change for fat reduction. Psychol Health. 1997;12:719-727.
Brug J, Steenhuis I, van Assema P, et al. The impact of a computer-tailored nutrition intervention. Prev Med. 1996;25:236-242. [pmid: 8781000].
Brug J, Steenhuis I, van Assema P, et al. Computer-tailored nutrition education: Differences between two interventions. Health Educ Res. 1999;14:249-256. [pmid: 10387504].
Bruning PF, Egger RJ, Gooskens AC, et al. Dietary intake, nutritional status and well-being of cancer patients: A prospective study. Eur J Cancer Clin Oncol. 1985;21:1449-1459. [pmid: 3830726].
Brunner E, White I, Thorogood M, et al. Can dietary interventions change diet and cardiovascular risk factors? A meta-analysis of randomized controlled trials. Am J Public Health. 1997;87:1415-1422. [pmid: 9314790]. [pmcid: 1380963].
Bruno MJ, Haverkort EB, Tijssen GP, et al. Placebo controlled trial of enteric coated pancreatin microsphere treatment in patients with unresectable cancer of the pancreatic head region. Gut. 1998;42:92-96. [pmid: 9505892].
Bruno R, Arnold C, Jacobson L, et al. Randomized controlled trial of a nonpharmacologic cholesterol reduction program at the worksite. Prev Med. 1983;12:523-532. [pmid: 6622436].
Buescher PA, Larson LC, Nelson MD, et al. Prenatal WIC participation can reduce low birth weight and newborn medical costs: A cost-benefit analysis of WIC participation in North Carolina. J Am Dietetic Assoc. 1993;93:163-166. [pmid: 8423280].
Buiatti E, Palli D, Amadori D, et al. Methodological issues in a multicentric study of gastric cancer and diet in Italy: Study design, data sources and quality controls. Tumori. 1989;75:410-419. [pmid: 2690430].
Bukovsky J, Evans A, Tartaglione M, et al. Selection of variant neuroblastoma cell line which has lost cell surface expression of antigen detected by monoclonal antibody PI153/3. Somatic Cell & Mol Genetics. 1985;11:517-522.
Buller DB, Morrill C, Taren D, et al. Randomized trial testing the effect of peer education at increasing fruit and vegetable intake. J Natl Cancer Inst. 1999;91:1491-1500. [pmid: 10469751].
Bulpitt CJ, Daymond M, Bulpitt PF, et al. Is low salt dietary advice a useful therapy in hypertensive patients with poorly controlled blood pressure?. Ann Clin Res. 1984;(16 suppl)43:143-149. [pmid: 6398984].
Buring JE, Hennekens CH. Current issues in cancer chemoprevention [review]. IARC Sci Publications. 1990;(103):185-193.
Burke V, Beilin LJ, Milligan R, et al. Assessment of nutrition and physical activity education programmes in children [review]. Clin Exp Pharmacol Physiol. 1995;22:212-216. [pmid: 7554417].
Burke V, Milligan RA, Thompson C, et al. A controlled trial of health promotion programs in 11-year-olds using physical activity 'enrichment' for higher risk children. J Pediatr. 1998;132:840-848. [pmid: 9602197].
Burr ML. Fish food, fish oil and cardiovascular disease. Clin Exp Hypertens -- Part A, Theory & Prac. 1992;14(1-2):181-192.
Burr ML, Fehily AM, Gilbert JF, et al. Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: Diet and reinfarction trial (DART). Lancet. 1989;2:757-761. [pmid: 2571009].
Burr ML, Fehily AM, Rogers S, et al. Diet and reinfarction trial (DART): Design, recruitment, and compliance. Eur Heart J. 1989;10:558-567. [pmid: 2547617].
Bye A, Ose T, Kaasa S. Quality of life during pelvic radiotherapy. Acta Obstetricia Et Gynecologica Scandinavica. 1995;74:147-152. [pmid: 7900512].
Byers T. Nutritional risk factors for breast cancer. Cancer. 1994;74(1 suppl):288-295. [pmid: 8004599].
Callahan EH, Paris B. Midlife periodic health exam in the primary care practice. Geriatr. 1997;52:60-76.
Calle-Pascual AL, Rodriguez C, Camacho F, et al. Behaviour modification in obese subjects with type 2 diabetes mellitus. Diabetes Res Clin Prac. 1992;15:157-162.
Cameron E, Bland J, Marcuson R. Divergent effects of Omega-6 and Omega-3 fatty acids on mammary tumor development in C3H/Heston mice treated with DMBA. Nutr Res. 1989;9:383-393.
Campa MJ, Schreiber G, Bepler G, et al. Characterization of delta opioid receptors in lung cancer using a novel nonpeptidic ligand. Cancer Res. 1996;56:1695-1701. [pmid: 8603422].
Campbell LV, Barth R, Gosper JK, et al. Impact of intensive educational approach to dietary change in NIDDM. Diabetes Care. 1990;13:841-847. [pmid: 2209318].
Campbell MK, Demark-Wahnefried W, Symons M, et al. Fruit and vegetable consumption and prevention of cancer: The Black Churches United for Better Health project. Am J Public Health. 1999;89:1390-1396. [pmid: 10474558]. [pmcid: 1508774].
Campbell MK, Honess-Morreale L, Farrell D, Carbone E, Brasure M. A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. Health Educ Res. 1999;14:257-267. [pmid: 10387505].
Campbell NC, Ritchie LD, Thain J, et al. Secondary prevention in coronary heart disease: A randomised trial of nurse led clinics in primary care. Heart. 1998;80:447-452. [pmid: 9930042].
Campos CT, Matts JP, Santilli SM, et al. Predictors of total and low-density lipoprotein cholesterol change after partial ileal bypass. Am J Surg. 1988;155:138-146. [pmid: 3341527].
Carey TS. Occupational back pain: issues in prevention and treatment. [review]. Baillieres Clin Rheumatol. 1989;3:143-156. [pmid: 2525428].
Carey TS. Chronic back pain: Behavioral interventions and outcomes in a changing healthcare environment. Behav Med. 1994;20:113-117. [pmid: 7865930].
Carey TS. Disability: how successful are we in determining disability? [review]. Neurol Clin. 1999;17:167-178. [pmid: 9855677].
Carey TS, Bennard B. Involvement of three types of preceptors with residents in an ambulatory care clinic. J Med Educ. 1988;63:479-482. [pmid: 3373508].
Carey TS, Evans A, Hadler N, et al. Care-seeking among individuals with chronic low back pain. Spine. 1995;20:312-317. [pmid: 7732467].
Carey TS, Evans AT, Hadler NM, et al. Acute severe low back pain. A population-based study of prevalence and care-seeking. Spine. 1996;21:339-344. [pmid: 8742211].
Carey TS, Fletcher SW, Fletcher R, et al. Social Security disability determinations: Knowledge and attitudes of consultative physicians. Med Care. 1987;25:267-275. [pmid: 3695646].
Carey TS, Garrett J. Patterns of ordering diagnostic tests for patients with acute low back pain: The North Carolina Back Pain Project. Ann Intern Med. 1996;125:807-814. [pmid: 8928987].
Carey TS, Garrett JM, Jackman A, et al. Recurrence and care seeking after acute back pain: Results of a long-term follow-up study -- North Carolina Back Pain Project. Med Care. 1999;37:157-164. [pmid: 10024120].
Carey TS, Garrett J, Jackman A, et al. The outcomes and costs of care for acute low back pain among patients seen by primary care practitioners, chiropractors, and orthopedic surgeons: The North Carolina Back Pain Project. N Engl J Med. 1995;333:913-917. [pmid: 7666878].
Carey TS, Garrett J, Jackman A, et al. Reporting of acute low back pain in a telephone interview: Identification of potential biases. Spine. 1995;20:787-790. [pmid: 7701391].
Carey TS, Hadler NM. The role of the primary physician in disability determination for Social Security insurance and workers' compensation. Ann Intern Med. 1986;104:706-710. [pmid: 2938531].
Carey TS, Hadler NM, Gillings D, et al. Medical disability assessment of the back pain patient for the Social Security Administration: The weighting of presenting clinical features. J Clin Epidemiol. 1988;41:691-697. [pmid: 2969407].
Carey TS, Holcombe BJ. Endotracheal intubation as a risk factor for complications of nasoenteric tube insertion. Crit Care Med. 1991;19:427-429. [pmid: 1999107].
Carey TS, Kinsinger L, Keyserling T, et al. Research in the community: Recruiting and retaining practices. J Community Health. 1996;21:315-327. [pmid: 8894959].
Carey TS, Levis D, Pickard CG, et al. Development of a model quality-of-care assessment program for adult preventive care in rural medical practices. Quality Rev Bull. 1991;17:54-59.
Carey TS, Thomas D, Woolsey A, et al. Half a loaf is better than waiting for the bread truck. A computerized mini-medical record for outpatient care. Arch Intern Med. 1992;152:1845-1849. [pmid: 1520051].
Carey TS, Weis K. Diagnostic testing and return visits for acute problems in prepaid, case-managed Medicaid plans compared with fee-for-service. Arch Intern Med. 1990;150:2369-2372. [pmid: 2241447].
Carey TS, Weis K, Homer C. Prepaid versus traditional Medicaid plans: Lack of effect on pregnancy outcomes and prenatal care. Health Serv Res. 1991;26:165-181. [pmid: 2061055].
Carlsson R. Serum cholesterol, lifestyle, working capacity and quality of life in patients with coronary artery disease: Experiences from a hospital-based secondary prevention programme. Scandinavian Cardiovasc J Supplement. 1998;50:1-20.
Carmody TP, Istvan J, Matarazzo JD, et al. Applications of social learning theory in the promotion of heart-healthy diets: The Family Heart Study dietary intervention model. Health Educ Res. 1:13-27.
Carter-Edwards L, Bynoe MJ, Svetkey LP. Knowledge of diet and blood pressure among African Americans: Use of focus groups for questionnaire development. Ethnicity and Dis. 1998;8:184-197.
Cats A, Kleibeuker JH, Van der Meer R, et al. Randomized, double-blinded, placebo-controlled intervention study with supplemental calcium in families with hereditary nonpolyposis colorectal cancer. J Natl Cancer Inst. 1995;87:598-603. [pmid: 7752258].
Chan CK, Mueller N, Evans A, et al. Epstein-Barr virus antibody patterns preceding the diagnosis of nasopharyngeal carcinoma. Cancer Causes & Control. 1991;2:125-131. [pmid: 1651778].
Chance B, Borer E, Evans A, et al. Optical and nuclear magnetic resonance studies of hypoxia in human tissue and tumors. Ann N Y Acad Sci. 1988;551:1-161-16.
Cheadle A, Psaty BM, Diehr P, et al. Evaluating community-based nutrition programs: Comparing grocery store and individual-level survey measures of program impact. Prev Med. 1995;24:71-79. [pmid: 7740018].
Cheraskin E, Ringsdorf WM Jr, Setyaadmadja AT, et al. Cancer proneness profile: A study in weight and blood glucose. Geriatrics. 1968;23:134-137. [pmid: 5643034].
Childers JM, Chu J, Voigt LF, et al. Chemoprevention of cervical cancer with folic acid: A phase III Southwest Oncology Group Intergroup Study. Cancer Epidemiol, Biomarkers Prev. 1995;4:155-159. [pmid: 7742723].
Childers SR, Fleming LM, Selley DE, et al. BW373U86: A nonpeptidic delta-opioid agonist with novel receptor-G protein-mediated actions in rat brain membranes and neuroblastoma cells. Mol Pharmacol. 1993;44:827-834. [pmid: 8232233].
Chinchilli VM, Martel JK, Kumanyika S, et al. A weighted concordance correlation coefficient for repeated measurement designs. Biometrics. 1996;52:341-353. [pmid: 8934601].
Chlebowski RT, Blackburn GL, Buzzard IM, et al. Adherence to a dietary fat intake reduction program in postmenopausal women receiving therapy for early breast cancer: The Women's Intervention Nutrition Study. J Clin Oncol. 1993;11:2072-2080. [pmid: 8229121].
Chlebowski RT, Grosvenor M. The scope of nutrition intervention trials with cancer-related endpoints. [review]. Cancer. 1994;74(9 suppl):2734-2738. [pmid: 7954294].
Chlebowski RT, Palomares MR, Lillington L, et al. Recent implications of weight loss in lung cancer management. Nutrition. 1996;12(1 suppl):S43-47. [pmid: 8850220].
Christen WG, Gaziano JM, Hennekens CH. Design of Physicians' Health Study II -- a randomized trial of beta-carotene, vitamins E and C, and multivitamins, in prevention of cancer, cardiovascular disease, and eye disease, and review of results of completed trials. Ann Epidemiol. 2000;10:125-134. [pmid: 10691066].
Clark LC, Combs GF Jr, Turnbull BW, et al. Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin: A randomized controlled trial. JAMA. 1996;276:1957-1963. [pmid: 8971064].
Clark LC, Dalkin B, Krongard A, et al. Decreased incidence of prostate cancer with selenium supplementation: Results of a double-blind cancer prevention trial. Br J Urology. 1998;81:730-734. [pmid: 9634050].
Clemens MR. Free radicals in chemical carcinogenesis. Klinische Wochenschrift. 1991;69(21-23):1123-1134. [pmid: 1798290].
Cloos J, Bongers V, Lubsen H, et al. Lack of effect of daily N-acetylcysteine supplementation on mutagen sensitivity. Cancer Epidemiol, Biomarkers Prev. 1996;5:941-944. [pmid: 8922306].
Coates RJ, Bowen DJ, Kristal AR, et al. The Women's Health Trial Feasibility Study in Minority Populations: Changes in dietary intakes. Am J Epidemiol. 1999;149:1104-1112. [pmid: 10369504].
Cohen RY, Felix MR, Brownell KD. The role of parents and older peers in school-based cardiovascular prevention programs: Implications for program development. Health Educ Q. 1989;16:245-253. [pmid: 2732066].
Cohen SJ, Weinberger MH, Fineberg NS, et al. The effect of a household partner and home urine monitoring on adherence to a sodium restricted diet. Social Sci Med. 1991;32:1057-1061.
Colson JS, Green NR. Effectiveness of a nutrition education program designed for sodium reduction in hypertensive versus normotensive elderly. J Nutr Elderly. 1991;11(1-2):31-47.
Combs GF Jr, Clark LC, Turnbull BW. Reduction of cancer mortality and incidence by selenium supplementation. Medizinische Klinik. 1997;92(3 suppl):42-45. [pmid: 9342915].
Connor SL, Gustafson JR, Artaud-Wild SM, et al. The cholesterol-saturated fatindex for coronary prevention: background, use, and a comprehensive table of foods. J Am Diet Assoc. 1989;89:807-816. [pmid: 2723305].
Cook NR, Cohen J, Hebert PR, et al. Implications of small reductions in diastolic blood pressure for primary prevention. Arch Intern Med. 1995;155:701-709. [pmid: 7695458].
Copeland AR. Control theory and dietary change. J Reality Therapy. 1992;11:17-19.
Copperman N, Haas T, Arden MR, et al. Multidisciplinary intervention in adolescents with cardiovascular risk factors. Ann of the N Y Acad Sci. 1997;817:199-207. [pmid: 9239189].
Coultas DB, Samet JM. Occupational lung cancer. Clin Chest Med. 1992;13:341-354. [pmid: 1511558].
Cowan R, Britton PJ, Logue E, et al. The relationship among the transtheoretical model of behavioral change, psychological distress, and diet attitudes in obesity: Implications for primary care intervention. J Clin Psychol Med Settings. 1995;2:249-267.
Cowen D, Tardieu C, Schubert M, et al. Low energy Helium-Neon laser in the prevention of oral mucositis in patients undergoing bone marrow transplant: Results of a double blind randomized trial. Int J Radiation Oncol, Biol, Physics. 1997;38:697-703.
Cowie CC, Harris MI. Ambulatory medical care for non-Hispanic whites, African-Americans; and Mexican-Americans with NIDDM in the U.S. Diabetes Care. 1997;20:142-147. [pmid: 9118761].
Cox RH, Parker GG, Watson AC, et al. Dietary cancer risk of low-income women and change with intervention. J Am Diet Assoc. 1995;95:1031-1034. [pmid: 7657907].
Cristofanilli M, Hortobagyi GN. Current methods to prevent the development of breast cancer. In Vivo. 1998;12:659-665. [pmid: 9891229].
Crosley CJ, Rorke LB, Evans A, et al. Central nervous system lesions in childhood leukemia. Neurology. 1978;28:678-685. [pmid: 276657].
Crossman J, Eyjolfsson K. Perceptions of participants regarding the long-term impact of an education and support program for heart attack and heart surgery patients and their partners. J Community Psychol. 19:333-336.
Cucherat M, Boissel JP. Meta-analysis of results from clinical trials on prevention of coronary heart disease by lipid lowering interventions. Clin Trials & Meta-Analysis. 1993;28:109-129.
Cullen KW, Bartholomew LL, Parcel GS. Girl scouting: An effective channel for nutrition education. J Nutr Educ. 1997;29:86-91.
Cullen KW, Bartholomew LK, Parcel GS, et al. Measuring stage of change for fruit and vegetable consumption in 9- to 12-year-old girls. J Behav Med. 1998;21:241-254. [pmid: 9642570].
Cupples ME, McKnight A. Randomised controlled trial of health promotion in general practice for patients at high cardiovascular risk. BMJ. 1994;309(6960):993-996. [pmid: 7950723].
Currie CE, Amos A, Hunt SM. The dynamics and processes of behavioural change in five classes of health-related behaviour: Findings from qualitative research. Health Educ Res. 1991;6:443-453.
Curry S. Cessation from tobacco use [review]. Cancer Causes & Control. 1997;8(1 suppl):S9-11. [pmid: 9427414].
Curry S, Zucker A, Trautmann J. Even dying must be edited: Further thoughts on Joan Robinson. J Med Ethics. 1981;7:34-36. [pmid: 7205894].
Curry SJ, Kristal AR, Bowen DJ. An application of the stage model of behavior change to dietary fat reduction. Health Educ Res. 1992;7:97-105. [pmid: 10148734].
Cutler JA. Randomized clinical trials of weight reduction in nonhypertensive persons. Ann Epidemiol. 1991;1:363-370. [pmid: 1669517].
Cutter GR, Burke GL, Dyer AR, et al. Cardiovascular risk factors in young adults: The CARDIA baseline monograph. Controlled Clin Trials. 1991;12(1 suppl):1S-77S. [pmid: 1851696].
Czeizel AE, Kalina A, Williams RR. Euphenic prevention of coronary artery disease. Am J Cardiol. 1997;79:140-144. [pmid: 9193012].
Dahl BR, Read MH. Effect of a nutrition education program on the reduction of serum cholesterol level in Veterans Administration outpatients. J Am Diet Assoc. 1995;95:702-703. [pmid: 7759750].
D'Angio G, Evans A, Breslow N, et al. Management of children with Wilms' tumor: Defining the risk-benefit ratio. Frontiers of Radiat Ther & Oncol. 1981;16:30-39.
D'Angio GJ, Breslow N, Beckwith JB, et al. Treatment of Wilms' tumor: Results of the Third National Wilms' Tumor Study. Cancer. 1989;64:349-360. [pmid: 2544249].
D'Angio GJ, Evans A, Breslow N, et al. The treatment of Wilms' tumor: Results of the Second National Wilms' Tumor Study. Cancer. 1981;47:2302-2311. [pmid: 6164480].
D'Angio GJ, Meadows A, Mike V, et al. Decreased risk of radiation-associated second malignant neoplasms in actinomycin-D-treated patients. Cancer. 1976;37(2 suppl):1177-1185. [pmid: 1253130].
Daniels L, Gifford RW. Therapy for older adults who are hypertensive. Geriatr Nurs. 1980;1:37-39.
Davidson DM. Cardiovascular risk reduction in postmenopausal women. J Nutr Elderly. 1986;5:3-10.
Daviglus ML, Dyer AR, Persky V, et al. Dietary beta-carotene, vitamin C, and risk of prostate cancer: Results from the Western Electric Study. Epidemiol. 1996;7:472-477.
Davis-McFarland E, Trickey B, Reigart B, et al. Using focus groups to identify lifestyle and health issues in the elderly. Gerontol Geriatr Educ. 1998;18:33-50.
DeBusk RF, Miller NH, Superko HR, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Ann Intern Med. 1994;120:721-729. [pmid: 8147544].
DeCosse JJ, Miller HH, Lesser ML. Effect of wheat fiber and vitamins C and E on rectal polyps in patients with familial adenomatous polyposis. J Natl Cancer Inst. 1989;81:1290-1297. [pmid: 2549261].
De Lorgeril M, Renaud S, Mamelle N, et al. Mediterranean alpha-linolenic acid-rich diet in secondary prevention of coronary heart disease. Lancet. 1994;343(8911):1454-1459. [pmid: 7911176].
De Lorgeril M, Salen P, Caillat-Vallet E, et al. Control of bias in dietary trial to prevent coronary recurrences: The Lyon Diet Heart Study. Eur J Clin Nutr. 1997;51:116-122. [pmid: 9049571].
De Lorgeril M, Salen P, Martin JL, et al. Effect of a Mediterranean type of diet on the rate of cardiovascular complications in patients with coronary artery disease: Insights into the cardioprotective effect of certain nutriments. J Am Coll Cardiol. 1996;28:1103-1108. [pmid: 8890801].
De Lorgeril M, Salen P, Martin JL, et al. Mediterranean dietary pattern in a randomized trial: Prolonged survival and possible reduced cancer rate. Arch Intern Med. 1998;158:1181-1187. [pmid: 9625397].
De Lorgeril M, Salen P, Martin JL, et al. Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: Final report of the Lyon Diet Heart Study. Circulation. 1999;99:779-785. [pmid: 9989963].
Denke MA. Cholesterol-lowering diets: A review of the evidence. Arch Intern Med. 1995;155:17-26. [pmid: 7802517].
Denke MA. Weight loss as an endpoint: Measuring the effectiveness of treatment in obesity. Endocrinologist. 1996;6:375-383.
Di Buono M, Hannah JS, Katzel LI, et al. Weight loss due to energy restriction suppresses cholesterol biosynthesis in overweight, mildly hypercholesterolemic men. J Nutr. 1999;129:1545-1548. [pmid: 10419988].
Di Giulio P, Valsania I, Camerata OM, et al. Context and background after an infarction. Giornale Italiano Di Cardiologia. 1998;28:281-287. [pmid: 9561883].
Dixon LB, Shannon BM, Tershakovec AM, et al. Effects of family history of heart disease, apolipoprotein E phenotype, and lipoprotein(A) on the response of children's plasma lipids to change in dietary lipids. Am J Clin Nutr. 1997;66:1207-1217. [pmid: 9356540].
Dodson PM, Pacy PJ, Cox EV. Long-term follow-up of the treatment of essential hypertension with a high-fibre, low-fat and low-sodium dietary regimen. Human Nutr -- Clin Nutr. 1985;39:213-220.
Dolecek TA, Milas NC, Van Horn LV, et al. A long-term nutrition intervention experience: Lipid responses and dietary adherence patterns in the Multiple Risk Factor Intervention Trial. J Am Diet Assoc. 1986;86:752-758. [pmid: 3519737].
Doll R, Peto R. The causes of cancer: Quantitative estimates of avoidable risks of cancer in the United States today. J Natl Cancer. 1981;66:1191-1308. [pmid: 7017215].
Domel SB, Baranowski T, Davis H, et al. Fruit and vegetable food frequencies by fourth and fifth grade students: Validity and reliability. J Am Coll Nutr. 1994 Feb;13(1):33-39. [pmid: 7518727].
Domel SB, Baranowski T, Davis H, et al. Development and evaluation of a school intervention to increase fruit and vegetable consumption among 4th and 5th grade students. J Nutr Educ. 1993;25:345-349.
Domel SB, Baranowski T, Leonard SB, et al. Accuracy of fourth- and fifth-grade students' food records compared with school-lunch observations. Am J Clin Nutr. 1994;59 (1 suppl):218S-220S. [pmid: 8279428].
Domel SB, Baranowski T, Leonard SB, et al. Defining the year 2000 fruit and vegetable goal. J Am Coll Nutr. 1993;12:669-675. [pmid: 8294722].
Doshi NJ, Hurley RS, Garrison ME, et al. Effectiveness of a nutrition education and physical fitness training program in lowering lipid levels in the Black elderly. J Nutr Elderly. 1994;13:23-33.
Downs JR, Beere PA, Whitney E, et al. Design and rationale of the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Am J Cardiol. 1997;80:287-293. [pmid: 9264420].
Downs JR, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: Results of AFCAPS/TexCAPS. JAMA. 1998;279:1615-1622. [pmid: 9613910].
Dreher ML, Maher CV, Kearney P. The traditional and emerging role of nuts in healthful diets. Nutr Rev. 1996;54:241-245. [pmid: 8961751].
Duncan AM, Merz BE, Xu X, et al. Soy isoflavones exert modest hormonal effects in premenopausal women. J Clin Endocrinol Metabolism. 1999;84:192-197.
Dunstan DW, Mori TA, Puddey IB, et al. A randomised, controlled study of the effects of aerobic exercise and dietary fish on coagulation and fibrinolytic factors in type 2 diabetics. Thrombosis & Haemostasis. 1999;81:367-372. [pmid: 10102462].
Dunstan DW, Mori TA, Puddey IB, et al. The independent and combined effects of aerobic exercise and dietary fish intake on serum lipids and glycemic control in NIDDM: A randomized controlled study. Diabetes Care. 1997;20:913-921. [pmid: 9167099].
DuRant RH, Baranowski T, Rhodes T, et al. Association among serum lipid and lipoprotein concentrations and physical activity, physical fitness, and body composition in young children. J Pediatr. 1993;123:185-192. [pmid: 8345412].
Dwyer JT, Hewes LV, Mitchell PD, et al. Improving school breakfasts: Effects of the CATCH Eat Smart Program on the nutrient content of school breakfasts. Prev Med. 1996;25:413-422. [pmid: 8818065].
Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism: Clin Exp. 1997;46(12 suppl 1):50-55.
Ebrahim S, Smith GD. Systematic review of randomised controlled trials of multiple risk factor interventions for preventing coronary heart disease. BMJ. 1997;314(7095):1666-1674. [pmid: 9193292].
Eck LH, Klesges RC, Hanson CL, et al. A comparison of four commonly used nutrient database programs. J Am Diet Assoc. 1988;88:602-604. [pmid: 3367021].
Eckman MH, McNutt RA, Parkinson DR, et al. The timing of radical cystectomy after recent myocardial infarction: Waiting for Godot [clinical conference]. Med Decision Making. 1987;7:52-66.
Edmundson E, Parcel GS, Feldman HA, et al. The effects of the child and adolescent trial for cardiovascular health upon psychosocial determinants of diet and physical activity behavior. Prev Med. 1996;25:442-454. [pmid: 8812822].
Elmer PJ, Grimm RH Jr, Flack J, et al. Dietary sodium reduction for hypertension prevention and treatment. Hypertension. 1991;17(1 suppl):I182-I189. [pmid: 1987001].
Elmer PJ, Grimm R Jr, Laing B, et al. Lifestyle intervention: Results of the Treatment of Mild Hypertension Study (TOMHS). Prev Med. 1995;24:378-388. [pmid: 7479629].
Elton PJ, Ryman A, Hammer M, et al. Randomised controlled trial in northern England of the effect of a person knowing their own serum cholesterol concentration. J Epidemiol Community Health. 1994;48:22-25. [pmid: 8138763].
Ericsson CG, Hamsten A, Nilsson J, et al. Angiographic assessment of effects of bezafibrate on progression of coronary artery disease in young male postinfarction patients. Lancet. 1996;347(9005):849-853. [pmid: 8622389].
Ernst ND, Obarzanek E. Child health and nutrition: Obesity and high blood cholesterol [review]. Prev Med. 1994;23:427-436. [pmid: 7971869].
Ershow AG, Zheng SF, Li GY, et al. Compliance and nutritional status during feasibility study for an intervention trial in China. J Natl Cancer Inst. 1984;73:1477-1481. [pmid: 6595459].
Espeland MA, Kumanyika S, Kostis JB, et al. Antihypertensive medication use among recruits for the Trial of Nonpharmacologic Interventions in the Elderly (TONE). J Am Geriatr Society. 1996;44:1183-1189.
Esper E, Glagov S, Karp RB, et al. Role of hypercholesterolemia in accelerated transplant coronary vasculopathy: Results of surgical therapy with partial ileal bypass in rabbits undergoing heterotopic heart transplantation. J Heart & Lung Transplantation. 1997;16:420-435.
Evans A. Lipids and cardiovascular disease: Ephemeral and elusive receptors. Q J Med. 1993;86:77-80. [pmid: 8464995].
Evans A. Difficulty in inserting a laryngeal mask airway. Anaesthesia. 1995;50:468-469. [pmid: 7793560].
Evans A, Lytwyn A, Urbach G, et al. Bilateral lymphangiomas of the ovary: An immunohistochemical characterization and review of the literature. Int J Gynecolog Pathol. 1999;18:87-90.
Evans A, Main E, Zier K, et al. The effects of gamma interferon on the natural killer and tumor cells of children with neuroblastoma: A preliminary report. Cancer. 1989;64:1383-1387. [pmid: 2505918].
Evans A, Pinder S, Wilson R, et al. Ductal carcinoma in situ of the breast: Correlation between mammographic and pathologic findings. Am J Roentgenol. 1994;162:1307-1311. [pmid: 8191988].
Evans A, Scher C, D'Angio G. Treatment of advanced neuroblastoma. Eur J Cancer. 1992;28A(8-9):1301-1302. [pmid: 1515236].
Evers SE, Bass M, Donner A, et al. Lack of impact of salt restriction advice on hypertensive patients. Prev Med. 1987;16:213-220. [pmid: 3588562].
Fager G, Wiklund O. Cholesterol reduction and clinical benefit: Are there limits to our expectations?. Arterioscl Thromb & Vascular Biol. 1997;17:3527-3533.
Faivre J, Couillault C, Kronborg O, et al. Chemoprevention of metachronous adenomas of the large bowel: Design and interim results of a randomized trial of calcium and fibre. Eur J Cancer Prev. 1997;6:132-138. [pmid: 9237061].
Faivre J, Giacosa A. Primary prevention of colorectal cancer through fibre supplementation. Eur J Cancer Prev. 1998;7(2 suppl):S29-S32.
Falk RJ, Hogan S, Carey TS, et al. Clinical course of anti-neutrophil cytoplasmic autoantibody-associated glomerulonephritis and systemic vasculitis: The Glomerular Disease Collaborative Network. Ann Intern Med. 1990;113:656-663. [pmid: 2221646].
FallCreek S, Mettler M. Healthy old age: A sourcebook for health promotion with older adults. J Gerontol Soc Work. 1983;6(2-3):1-313.
Farag SA, Mozar HN. Preventing recurrences of congestive heart failure. J Am Diet Assoc. 1967;51:26-28. [pmid: 6027630].
Farquhar JW, Maccoby N, Wood PD, et al. Community education for cardiovascular health. Lancet. 1977;1(8023):1192-1195. [pmid: 68285].
Farrand M. Multiple risk factor intervention trial. In: Tillotson JL, ed. Proceedings of the Nutrition-Behavioral Research Conference, pp. 11-14. Bethesda, MD: National Institutes of Health, 1976.
Fehily AM, Vaughan-Williams E, Shiels K, et al. The effect of dietary advice on nutrient intakes: Evidence from the diet and reinfarction trial (DART). J Human Nutr Diet. 1989;2:225-235.
Fernandes AO, Banerji AP. Long-term feeding of field bean protein containing protease inhibitors suppresses virus-induced mammary tumors in mice. Cancer Letters. 1997;116:1-7. [pmid: 9177450].
Ferri C, Bellini C, Desideri G, et al. Elevated plasma and urinary endothelin-I levels in human salt-sensitive hypertension. Clin Sci. 1997;93:35-41. [pmid: 9279201].
Fielding JE, Malotte CK, Neutra RR, et al. The description and initial evaluation of an intensive live-in program in risk reduction. Prev Med. 1983;12:447-464. [pmid: 6878203].
Fietkau R, Riepl M, Kettner H, et al. Supportive use of megestrol acetate in patients with head and neck cancer during radio(chemo)therapy. Eur J Cancer Part A. 1997;33:75-79.
Finklestein JZ, Klemperer MR, Evans A, et al. Multiagent chemotherapy for children with metastatic neuroblastoma: A report from Children's Cancer Study Group. Med Pediatr Oncol. 1979;6:179-188. [pmid: 460045].
Finnegan JR, Rooney B, Viswanath K, et al. Process evaluation of a home-based program to reduce diet-related cancer risk: The 'WIN At Home Series.'. Health Educ Q. 1992;19:233-248. [pmid: 1618630].
Finnegan JR, Viswanath K, Rooney B, et al. Predictors of knowledge about healthy eating in a rural midwestern US city. Health Educ Res. 1990;5:421-431.
Fitch LL, Buchwald H, Matts JP, et al. Effect of aspirin use on death and recurrent myocardial infarction in current and former cigarette smokers. Am Heart J. 1995;129:656-662. [pmid: 7900613].
Fitzgerald ST, Gibbens S, Agnew J. Evaluation of referral completion after a workplace cholesterol screening program. Am J Prev Med. 1991;7:335-340. [pmid: 1790040].
Fitzgibbon ML, Stolley MR, Avellone ME, et al. Involving parents in cancer risk reduction: A program for Hispanic American families. Health Psychol. 1996;15:413-422. [pmid: 8973920].
Fletcher V. An individualized teaching programme following primary uncomplicated myocardial infarction. J Advanced Nurs. 1987;12:195-200.
Foerster SB, Kizer KW, DiSogra LK, Bal DG. California's '5 a Day-for Better Health' Campaign: An innovative population-based effort to effect large-scale dietary change. Am J Prev Med. 1995;11:124-131. [pmid: 7632448].
Fontham ETH, Malcom GT, Singh VN, et al. Effect of beta-carotene supplementation on serum alpha-tocopherol concentration. Cancer Epidemiol, Biomarkers Prev. 1995;4:801-803. [pmid: 8673001].
Fossati P. Hypercholesterolemia; consensus and controversies on cholesterol lowering. What about it in 1993?. Annales d' Endocrinologie. 1993;54:389-397. [pmid: 7944281].
Frank E, Winkleby M, Fortmann SP, et al. Cardiovascular disease risk factors: Improvements in knowledge and behavior in the 1980s. Am J Public Health. 1993;83:590-593. [pmid: 8460744].
Franz MJ, Splett PL, Monk A, et al. Cost-effectiveness of medical nutrition therapy provided by dietitians for persons with non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1995;95:1018-1024. [pmid: 7657903].
Frascio F, Giacosa A, Sukkar SG, et al. Effects of soy fibers on bowel function during enteral nutrition. Rivista Italiana Di Nutrizione Parenterale Ed Enterale. 1994;12:90-95.
Frazier LM, Carey TS, Lyles MF, et al. Selective criteria may increase lumbosacral spine roentgenogram use in acute low-back pain. Arch Intern Med. 1989;149:47-50. [pmid: 2521444].
Frazier LM, Carey TS, Lyles MF, et al. Lengthy bed rest prescribed for acute low back pain: Experience at three general medicine walk-in clinics. South Med J. 1991;84:603-606. [pmid: 1827930].
Freimuth VS, Hammond SL, Stein JA. Health advertising: Prevention for profit. Am J Public Health. 1988;78:557-561. [pmid: 2833125].
Friedman DB, Williams AN, Levine BD. Compliance and efficacy of cardiac rehabilitation and risk factor modification in the medically indigent. Am J Cardiol. 1997;79:281-285. [pmid: 9036745].
Friedman RH. Automated telephone conversations to assess health behavior and deliver behavioral interventions. J Med Systems. 1998;22:95-102.
Friedman S, Kantor I, Sobel S, et al. A follow-up study on the chemotherapy of neurodermatitis with a monoamine oxidase inhibitor. J Nerv Ment Dis. 1978;166:349-357. [pmid: 650199].
Friedewald WT, Levy RI, Frederickson DS. Estimation of concentration of low-density lipoprotein cholesterol in plasma without the use of a preparative ultracentrifuge. Clin Chem. 1972;18:449-502. [pmid: 5019119].
Fries EA, Bowen DJ, Hopp HP, et al. Psychological effects of dietary fat analysis and feedback: A randomized feedback design. J Behav Med. 1997;20:607-619. [pmid: 9429991].
Friesinger GC, Ryan TJ. Coronary heart disease: Stable and unstable syndromes. Cardiol Clin. 1999;17:93-122. [pmid: 10093768].
Froom J, Froom P, Benjamin M, et al. Measurement and management of hyperlipidemia for the primary prevention of coronary heart disease. J Am Board Fam Prac. 1998;11:12-22.
Fuchs FD, Gus M, Moreira WD, et al. Blood pressure effects of antihypertensive drugs and changes in lifestyle in a Brazilian hypertensive cohort. J Hypertens. 1997;15:783-792. [pmid: 9222947].
Fumeron F, Betoulle D, Luc G, et al. Alcohol intake modulates the effect of a polymorphism of the cholesteryl ester transfer protein gene on plasma high density lipoprotein and the risk of myocardial infarction. J Clin Invest. 1995;96:1664-1671. [pmid: 7657837]. [pmcid: 185794].
Futrell M, Brovender S, McKinnon-Mullet E, et al. Primary Health Care of the Older Adult. North Scituate, MA: Duxbury Press, 1980.
Gairard B, Mathelin C, Schaffer P, et al. Breast cancer: Epidemiology, risk factors, screening. Revue du Praticien. 1998;48:21-27. [pmid: 9781206].
Galan P, Preziosi P, Triol I, et al. Antioxidants and prevention. Cahiers de Nutrition et de Dietetique. 1997;32:359-370.
Gambera PJ, Schneeman BO, Davis PA. Use of the Food Guide Pyramid and US Dietary Guidelines to improve. J Am Diet Assoc. 1995;95(11):1268-1273. [pmid: 7594122].
Gann PH, Ma J, Giovannucci E, et al. Lower prostate cancer risk in men with elevated plasma lycopene levels: Results of a prospective analysis. Cancer Res. 1999;59:1225-1230. [pmid: 10096552].
Gans KM, Lapane KL, Lasater TM, et al. Effects of intervention on compliance to referral and lifestyle recommendations given at cholesterol screening programs. Am J Prev Med. 1994;10:275-282. [pmid: 7848670].
Garay-Sevilla ME, Nava LE, Malacara JM, et al. Adherence to treatment and social support in patients with non-insulin dependent diabetes mellitus. J Diabetes & Its Complications. 1995;9:81-86.
Garber AM, Browner WS, Hulley SB. Cholesterol screening in asymptomatic adults, revisited. Ann Intern Med. 1996;124:518-531. [pmid: 8602715].
Garbutt JC, West SL, Carey TS, et al. Pharmacological treatment of alcohol dependence: A review of the evidence. JAMA. 1999;281:1318-1325. [pmid: 10208148].
Garcia A, Gutierrez JM, Fernandez S, et al. Dietary intervention in a hypercholesterolemic school-aged population from Northern Spain. Revista Espanola de Fisiologia. 1996;52:49-58. [pmid: 8774086].
Garrett G. Adding Health to Years: A Basic Handbook on Older People's Health. [Monograph] London: HelpAge International. 1993.
Gates G, McDonald M. Comparison of dietary risk factors for cardiovascular disease in African-American and white women. J Am Diet Assoc. 1997;97:1394-1400. [pmid: 9404336].
Gaziano JM, Hennekens CH. Update on dietary antioxidants and cancer. Pathologie et Biologie. 1996;44:42-45. [pmid: 8734299].
Gemson DH, Sloan RP, Messeri P, et al. A public health model for cardiovascular risk reduction. Impact of cholesterol screening with brief nonphysician counseling. Arch Intern Med. 1990;150:985-989. [pmid: 2331203].
Gey KF. Vitamins E plus C and interacting conutrients required for optimal health. A critical and constructive review of epidemiology and supplementation data regarding cardiovascular disease and cancer. Biofactors. 1998;7(1-2):113-174. [pmid: 9698234].
Gey KF, Stahelin HB, Puska P, et al. Relationship of plasma level of vitamin C to mortality from ischemic heart disease. Ann NY Acad Sci. 1987;498:110-123. [pmid: 3497600].
Gheorghiade M, Benatar D, Konstam MA, et al. Pharmacotherapy for systolic dysfunction: A review of randomized clinical trials. Am J Cardiol. 1997;80(8 B):14H-27H.
Giles WH, Kittner SJ, Croft JB, et al. Serum folate and risk for coronary heart disease: Results from a cohort of US adults. Ann Epidemiol. 1998;8:490-496. [pmid: 9802593].
Gillespie AH, Achterberg CL. Comparison of family interaction patterns related to food and nutrition. J Am Diet Assoc. 1989;89:509-512. [pmid: 2784810].
Given CW, Given BA, Coyle BW. Prediction of patient attrition from experimental behavioral interventions. Nurs Res. 1985;34:293-298. [pmid: 3900932].
Glanz K. Compliance with dietary regimens: Its magnitude, measurement, and determinants. Prev Med. 1980;9(6):787-804. [pmid: 7359302].
Glanz K. Nutrition education for risk factor reduction and patient education: A review [review]. Prev Med. 1985;14:721-752. [pmid: 3911200].
Glanz K. Patient and public education for cholesterol reduction: A review of strategies and issues [review]. Patient Educ Counsel. 1988;12:235-257.
Glanz K. Reducing breast cancer risk through changes in diet and alcohol intake: From clinic to community. Ann Behav Med. 1994;41:334-346.
Glanz K. Behavioral research contributions and needs in cancer prevention and control: Dietary change. Prev Med. 1997;26:S43-S55. [pmid: 9327492].
Glanz K. Progress in dietary behavior change. Am J Health Promot. 1999;14:112-117. [pmid: 10724722].
Glanz K, Brekke M, Harper D, et al. Evaluation of implementation of a cholesterol management program in physicians' offices. Health Educ Res. 1992;7:151-164. [pmid: 10148737].
Glanz K, Gilboy MB. Physicians, preventive care, and applied nutrition: Selected literature. Acad Med. 1992;67:776-781. [pmid: 1418261].
Glanz K, Hewitt AM, Rudd J. Consumer behavior and nutrition education: An integrative review. J Nutr Educ. 1992;24:267-277.
Glanz K, Kristal AR, Sorensen G, et al. Development and validation of measures of psychosocial factors influencing fat- and fiber-related dietary behavior. Prev Med. 1993;22:373-387. [pmid: 8392175].
Glanz K, Kristal AR, Tilley BC, et al. Psychosocial correlates of healthful diets among male auto workers. Cancer Epidemiol, Biomarkers Prev. 1998;7:119-126. [pmid: 9488586].
Glanz K, Lankenau B, Foerster S, et al. Environmental and policy approaches to cardiovascular disease prevention through nutrition: Opportunities for state and local action. Health Educ Q. 1995;22:512-527. [pmid: 8550374].
Glanz K, Lewis FM, Rimer BK. Health Behavior and Health Education: Theory, Research, and Practice. San Francisco, CA: Jossey-Bass, 1997.
Glanz K, Mullis RM. Environmental interventions to promote healthy eating: A review of models, programs, and evidence. Health Educ Q. 1988;15:395-415. [pmid: 3068206].
Glanz K, Patterson RE, Kristal AR, et al. Impact of work site health promotion on stages of dietary change: The Working Well Trial. Health Educ Behav. 1998;25:448-463. [pmid: 9690103].
Glanz K, Sorensen G, Farmer A. The health impact of worksite nutrition and cholesterol intervention programs. Am J Health Promotion. 1996;10:453-470.
Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Counseling. 1997;32:175-184.
Glasgow RE, Perry JD, Toobert DJ, et al. Brief assessments of dietary behavior in field settings. Addictive Behav. 1996;21:239-247.
Glasgow RE, Terborg JR, Hollis JF, et al. Modifying dietary and tobacco use patterns in the worksite: The Take Heart Project. Health Educ Q. 1994;21:69-82. [pmid: 8188494].
Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. 1996;19:835-842. [pmid: 8842601].
Glasgow RE, Toobert DJ, Hampson SE, et al. Improving self-care among older patients with type II diabetes: The 'sixty Something...' Study. Patient Educ Counseling. 1992;19:61-74.
Glasgow RE, Toobert DJ, Mitchell DL, et al. Nutrition education and social learning interventions for type II diabetes. Diabetes Care. 1989;12:150-152. [pmid: 2702897].
Goldberg SJ, Allen HD, Friedman G, et al. Use of health education and attempted dietary change to modify atherosclerotic risk factors: A controlled trial. Am J Clin Nutr. 1980;33:1272-1278. [pmid: 7386415].
Goldstein AO, Carey TS, Levis D, et al. Variations in hypertension control in indigent rural primary care clinics in North Carolina. Arch Fam Med. 1994;3:514-519. [pmid: 8081531].
Goodman GE. Cancer prevention: Chemoprevention vs dietary modifications. Prev Med. 1993;22:689-692. [pmid: 8234208].
Goodman MT, Hernandez B, Wilkens LR, et al. Effects of beta-carotene and alpha-tocopherol on bleomycin-induced chromosomal damage. Cancer Epidemiol, Biomarkers Prev. 1998;7:113-117. [pmid: 9488585].
Goodstein ML, Richtsmeier WJ, Sauer LA. The effect of an acute fast on human head and neck carcinoma xenograft: Growth effects on an 'isolated tumor vascular pedicle' in the nude rat. Arch Otolaryngol -- Head & Neck Surg. 1993;119:897-902. [pmid: 8343253].
Gorder DD, Doleck TA, Coleman GG, et al. Dietary intake in the multiple risk factor intervention trial (MRFIT): Nutrient and food group changes over 6 years. J Am Diet Assoc. 1986;86:744-751. [pmid: 3519736].
Graham S, Haughey B, Marshall J, et al. Diet in the epidemiology of gastric cancer. Nutr Cancer. 1990;13(1-2):19-34. [pmid: 2300492].
Gran B. Non-pharmacological methods reduce drug use in the treatment of hypertension. A 2-year trial in general practice. Scand J Primary Health Care. 1991;9:121-128.
Green LW, Kreuter MW, Deeds SG, et al. Health Education Planning: A Diagnostic Approach. Palo Alto, CA: Mayfield. 1980.
Greenberg ER, Baron JA, Karagas MR, et al. Mortality associated with low plasma concentration of beta carotene and the effect of oral supplementation. JAMA. 1996;275:699-703. [pmid: 8594267].
Greenberg ER, Baron JA, Tosteson TD, et al. A clinical trial of antioxidant vitamins to prevent colorectal adenoma. N Engl J Med. 1994;331:141-147. [pmid: 8008027].
Greene G. Behavior modification for adult onset diabetes. Diabetes Educator. 1981;7:11-15, 27. [pmid: 6909071].
Greene GW, Achterberg C, Crumbaugh J, et al. Dietary intake and dieting practices of bulimic and non-bulimic female college students. J Am Diet Assoc. 1990;90:576-578. [pmid: 2319081].
Greenwald P. Experience from clinical trials in cancer prevention. Ann Med. 1994;26:73-80. [pmid: 8166993].
Greenwald P. Cancer risk factors for selecting cohorts for large-scale chemoprevention trials. J Cellular Biochem. 1996;63(suppl 25):29-36.
Greenwald P, Clifford C, Pilch S, Heimendinger J, et al. New directions in dietary studies in cancer: The National Cancer Institute [review]. Advances in Exper Med Biol. 1995;369:229-239. [pmid: 7598012].
Greenwald P, Cullen JW. The new emphasis in cancer control. J Natl Cancer Inst. 1985;74:543-551. [pmid: 3883037].
Greenwald P, McDonald SS. Cancer prevention: The roles of diet and chemoprevention. Cancer Control. 1997;4:118-127. [pmid: 10763009].
Greenwald P, Sondik E, Lynch BS. Diet and chemoprevention in NCI's research strategy to achieve national cancer control objectives. Ann Rev Public Health. 1986;7:267-291. [pmid: 3013230].
Griffenberg L, Morris M, Atkinson N, et al. The effect of dietary fiber on bowel function following radical hysterectomy: A randomized trial. Gynecologic Oncol. 1997;66:417-424. [pmid: 9299255].
Grimm RH Jr, Flack JM, Grandits GA, et al. Long-term effects on plasma lipids of diet and drugs to treat hypertension. Treatment of Mild Hypertension Study (TOMHS) Research Group. JAMA. 1996;275:1549-1556. [pmid: 8622245].
Gritz ER, Bastani R. Cancer prevention: Behavior changes -- The short and the long of it. Prev Med. 1993;22(5):676-688. [pmid: 8234207].
Gritz ER, Carmack CL, De Moor C, et al. First year after head and neck cancer: Quality of life. J Clin Oncol. 1999;17:352-360. [pmid: 10458254].
Grundy P, Breslow N, Green DM, et al. Prognostic factors for children with recurrent Wilms' tumor: Results from the Second and Third National Wilms' Tumor Study. J Clin Oncol. 1989;7:638-647. [pmid: 2540289].
Gutierrez ML, Evans A, Rohrbaugh T, et al. Phase II evaluation of mitomycin C (MMC) in children with refractory solid tumors using the single high-intermittent-dose schedule. Med Pediat Oncol. 1981;9:405-407.
Gylling H, Radhakrishnan R, Miettinen TA. Reduction of serum cholesterol in postmenopausal women with previous myocardial infarction and cholesterol malabsorption induced by dietary sitostanol ester margarine: Women and dietary sitostanol. Circulation. 1997;96(12):4226-4231. [pmid: 9416886].
Haarbo J, Hansen BF, Christiansen C. Hormone replacement therapy prevents coronary artery disease in ovariectomized cholesterol-fed rabbits. APMIS. 1991;99:721-727. [pmid: 1907151].
Haber D, Lacy MG. Evaluation of a socio-behavioral intervention for changing health behaviors of older adults. Behav Health Aging. 1993;3:73-85.
Hadler NM, Carey TS. Low back pain: An intermittent and remittent predicament of life. Ann Rheum Dis. 1998;57:1-2. [pmid: 9536812].
Hadler NM, Carey TS, Garrett J. The influence of indemnification by workers' compensation insurance on recovery from acute backache. North Carolina Back Pain Project. Spine. 1995;20:2710-2715. [pmid: 8747249].
Haglund BJ, Tillgren P, Holm LE, et al. Mapping of the 'intervention channels' as a part of the community diagnosis process of the Stockholm Cancer Prevention Program (SCPP). Scand J Primary Health Care - Supplement. 1988;1:65-72.
Hakama M. Chemoprevention research in Europe. Int J Cancer. 1997;72(suppl):30-33. [pmid: 9209017].
Hamajima N. Stomach cancer: from epidemiology to prevention. Biotherapy. 1997;11:1073-1078.
Hamazaki T, Sawazaki S, Itomura M, et al. The effect of docosahexaenoic acid on aggression in young adults: A placebo-controlled double-blind study. J Clin Invest. 1996;97:1129-1133. [pmid: 8613538].
Hammond JE, Berger RG, Carey TS, et al. Making the transition from information systems of the 1970s to medical information systems of the 1990s: The role of the physician's workstation. J Med Systems. 1991;15:257-267.
Hammond JE, Berger RG, Carey TS, et al. The Physician's Workstation: An example of end user integration of information systems. Proc Annu Symp Compu Applications in Med Care. 1991:970-972.
Hammond JE, Berger RG, Carey TS, et al. Progress report on the clinical workstation and clinical data repository at UNC Hospitals. Proc Annu Symp Compu Applications in Med Care. 1993:243-247.
Hammond JE, Berger RG, Carey TS, et al. Report on the clinical workstation and clinical data repository utilization at UNC Hospitals. Proc Annu Symp Compu Applications in Med Care. 1994:276-80.
Hanefeld M, Fischer S, Schmechel H, et al. Diabetes intervention study: Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14:308-317. [pmid: 2060433].
Hanlon P, McEwen J, Carey L, et al. Health checks and coronary risk: Further evidence from a randomised controlled trial. BMJ. 1995;311(7020):1609-1613. [pmid: 8555805].
Harrell JS, Gansky SA, McMurray RG, et al. School-based interventions improve heart health in children with multiple cardiovascular disease risk factors. Pediatrics. 1998;102(2 Pt 1):371-380. [pmid: 9685441].
Harrell JS, McMurray RG, Bangdiwala SI, et al. Effects of a school-based intervention to reduce cardiovascular disease. J Pediatr. 1996;128:797-805. [pmid: 8648539].
Harris TB, Savage PJ, Tell GS, et al. Carrying the burden of cardiovascular risk in old age: Associations of weight and weight change with prevalent cardiovascular disease, risk factors, and health status in the Cardiovascular Health Study. Am J Clin Nutr. 1997;66:837-844. [pmid: 9322558].
Hartman IS. Alpha-linolenic acid: A preventive in secondary coronary events?. Nutr Rev. 1995;53:194-197. [pmid: 7494621].
Hartman TJ, Albanes D, Pietinen P, et al. The association between baseline vitamin E, selenium, and prostate cancer in the alpha-tocopherol, beta-carotene cancer prevention study. Cancer Epidemiol, Biomarkers Prev. 1998;7:335-340. [pmid: 9568790].
Hartman TJ, McCarthy PR, Park RJ, et al. Results of a community-based low-literacy nutrition education program. J Community Health. 1997;22:325-341. [pmid: 9353681].
Harvey W, Guat-Chen F, Gordon D, Meghji S, et al. Evidence for fibroblasts as the major source of prostacyclin and prostaglandin synthesis in dental cyst in man. Arch Oral Biol. 1984;29:223-229. [pmid: 6329148].
Haskell WL, Fair J, Sanders W, et al. New methodologies for studying the prevention of atherosclerosis. Ann Clin Res. 1988;20(1-2):39-45. [pmid: 3408211].
Hatton DC, Haynes RB, Oparil S, et al. Improved quality of life in patients with generalized cardiovascular metabolic disease on a prepared diet. Am J Clin Nutr. 1996;64:935-943. [pmid: 8942420].
Havas S, Anliker J, Damron D, et al. Final results of the Maryland WIC 5-A-Day Promotion Program. Am J Public Health. 1998;88:1161-1167. [pmid: 9702141]. [pmcid: 1508288].
Havas S, Heimendinger J, Damron D, et al. 5 A Day for better health -- nine community research projects to increase fruit and vegetable consumption. Public Health Rep. 1995;110:68-79. [pmid: 7838947].
Havas S, Heimendinger J, Reynolds K, et al. 5 a day for better health: A new research initiative. J Am Diet Assoc. 1994;94:32-36. [pmid: 8270753].
He J, Klag MJ, Appel LJ, et al. Seven-year incidence of hypertension in a cohort of middle-aged African Americans and whites. Hypertension. 1998;31:1130-1135. [pmid: 9576125].
Hedberg GE, Wikstrom-Frisen L, Janlert U. Comparison between two programmes for reducing the levels of risk indicators of heart diseases among male professional drivers. Occup Environ Med. 1998;55:554-561. [pmid: 9849543].
Hehr T, Hoffmann W, Bamberg M. The role of natrium selenite as adjuvants in radiotherapy of rectal cancer. Medizinische Klinik. 1997;92(3 suppl):48-49. [pmid: 9417501].
Heijnen M-LA, Van Amelsvoort JMM, Deurenberg P, et al. Limited effect of consumption of uncooked (RS2) or retrograded (RS3) resistant starch on putative risk factors for colon cancer in healthy men. Am J Clin Nutr. 1998;67:322-331. [pmid: 9459382].
Heimburger DC, Alexander CB, Birch R, et al. Improvement in bronchial squamous metaplasia in smokers treated with folate and vitamin B12: Report of a preliminary randomized, double-blind intervention trial. J Am Med Assoc. 1988;259:1525-1530. [pmid: 3339790].
Heimendinger J, Feng Z, Emmons K, et al. The Working Well Trial: Baseline dietary and smoking behaviors of employees and related worksite characteristics. Prev Med. 1995;24:180-193. [pmid: 7597021].
Heimendinger J, Foerster S, Kaufman M, et al. Nutrition and cancer prevention activities in state health agencies. Health Educ Res. 5(4):545-550.
Heinonen OP, Albanes D, Virtamo J, et al. Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: Incidence and mortality in a controlled trial. J Natl Cancer Inst. 1998;90:440-446. [pmid: 9521168].
Heinonen OP, Huttunen JK, Albanes D, et al. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330:1029-1035. [pmid: 8127329].
Heinonen OP, Huttunen JK, Albanes D, et al. The Alpha-Tocopherol, Beta-Carotene Lung Cancer Prevention Study: Design, methods, participant characteristics, and compliance. Ann Epidemiol. 1994;4:1-10. [pmid: 8205268].
Heller RF, Elliott H, Bray AE, et al. Reducing blood cholesterol levels in patients with peripheral vascular disease: Dietitian or diet fact sheet?. Med J Aust. 1989;151:566-568. [pmid: 2593891].
Heller RF, Walker RJ, Boyle CA, et al. A randomised controlled trial of a dietary advice program for relatives of heart attack victims. Med J Aust. 1994;161:529-531. [pmid: 7968751].
Heller SR, Clarke P, Daly H, et al. Group education for obese patients with type 2 diabetes: Greater success at less cost. Diabetic Med. 1988;5:552-556. [pmid: 2974778].
Hempel RJ. Physician documentation of diabetes care: Use of a diabetes flow sheet and patient education clinic. South Med J. 1990;83:1426-1432. [pmid: 2251531].
Henderson M. Opportunities for research on prevention of breast cancer. Cancer Prev Control. 1997;1:133-137. [pmid: 9765735].
Henderson MM. Role of intervention trials in research on nutrition and cancer. Cancer Res. 1992;52(7 suppl):2030s-2034s. [pmid: 1544137].
Henderson MM. Nutritional aspects of breast cancer. Cancer. 1995;76(10 suppl):2053-2058. [pmid: 8634999].
Henderson MM, Kushi LH, Thompson DJ, et al. Feasibility of a randomized trial of a low-fat diet for the prevention of breast cancer: Dietary compliance in the Women's Health Trial Vanguard Study. Prev Med. 1990;19:115-133. [pmid: 2193306].
Hennekens CH. Antioxidant vitamins and cancer. Am J Med. 1994;97(3A):2S-4S. [pmid: 8085583].
Hennekens CH, Gaziano JM. Antioxidants and heart disease: Epidemiology and clinical evidence. Clin Cardiol. 1993;16(4 suppl):I10-I15. [pmid: 8472392].
Hennekens CH, Gaziano JM, Manson JE, et al. Antioxidant vitamin-cardiovascular disease hypothesis is still promising, but still unproven: The need for randomized trials. Am J Clin Nutr. 1995;62(6 suppl):1377S-1380S. [pmid: 7495234].
Henquin N, Havivi E, Reshef A, et al. Nutritional monitoring and counselling for cancer patients during chemotherapy. Oncology. 1989;46:173-177. [pmid: 2717128].
Hercberg S, Galan P, Preziosi P, et al. The potential role of antioxidant vitamins in preventing cardiovascular diseases and cancers. Nutrition. 1998;14:513-520. [pmid: 9646292].
Hercberg S, Preziosi P, Briancon S, et al. A primary prevention trial using nutritional doses of antioxidant vitamins and minerals in cardiovascular diseases and cancers in a general population: The SU.Vi.Max study: Design, methods, and participant characteristics. Control Clin Trials. 1998;19:336-351. [pmid: 9683310].
Herrick AB, Stone WJ, Mettler MM. Stages of change, decisional balance, and self-efficacy across four health behaviors in a worksite environment. Am J Health Promotion. 1997;12:49-56.
Herrmann SM, Poirier O, Nicaud V, et al. Identification of two polymorphisms in the promoter of the microsomal triglyceride transfer protein (MTP) gene: Lack of association with lipoprotein profiles. J Lipid Res. 1998;39(12):2432-2435. [pmid: 9831631].
Hersey JC, Burnbauer L, Bellamy H, et al. Progress and accomplishments of the statewide nutrition education network cooperative agreement program: Year one. Report to the Food and Consumer Service, USDA (Contract No. FCS-53-3198-5-038), Research Triangle Park, NC: Research Triangle Institute and Health Systems Research, 1997.
Hertog JK, Finnegan JR, Rooney B, et al. Self-efficacy as a target population segmentation strategy in a diet and cancer risk reduction campaign. Health Commun. 1993;5:21-40.
Heyden S, Kluthe R, Immenhofer C. International Symposium on Sodium and Hypertension. Results of randomized trials. Clin Investigator. 1994;72:800-803.
Hill MJ. Problems in giving dietary advice for cancer prevention [editorial]. Eur J Cancer Prev. 1994;3:303-304. [pmid: 7950883].
Hill MJ. Diet and chemoprevention of colorectal cancer. Tumori. 1995;81(3 suppl):5-6. [pmid: 7571053].
Hirohata I, Fukuda K, Shibata A, et al. Reproducibility of reports of past history, smoking, drinking and dietary habits obtained by a personal interview for a case-control study on liver cirrhosis and hepatocellular carcinoma. Kurume Med J. 1991;38:243-249. [pmid: 1668674].
Hiss RG. Barriers to care in non-insulin-dependent diabetes mellitus. The Michigan experience. Ann Intern Med. 1996;124(1 Pt 2):146-148. [pmid: 8554207].
Hjermann I, Velve Byre K, Holme I, et al. Effect of diet and smoking intervention on the incidence of coronary. Lancet. 1981;2(8259):1303-1310. [pmid: 6118715].
Ho EE, Atwood JR, Benedict J, et al. A community-based feasibility study using wheat bran fiber supplementation to lower colon cancer risk. Prev Med. 1991;20:213-225. [pmid: 1647531].
Ho EE, Lee FC, Meyskens FL Jr. An exploratory study of attitudes, beliefs and practices related to the interim dietary guidelines for reducing cancer in the elderly. J Nutr Elderly. 1991;10:31-49.
Hoelund U. Promoting change of adolescents' sugar consumption: The 'learning by teaching' study. Health Educ Res. 1990;5:451-458.
Hofstad B, Almendingen K, Vatn M, et al. Growth and recurrence of colorectal polyps: A double-blind 3-year intervention with calcium and antioxidants. Digestion. 1998;59:148-156. [pmid: 9586828].
Hofstad B, Vatn M, Hoff G, et al. Growth of colorectal polyps: Design of a prospective, randomized, placebo-controlled intervention study in patients with colorectal polyps. Eur J Cancer Prev. 1992;1:415-422. [pmid: 1463996].
Hollis JF, Satterfield S, Smith F, et al. Recruitment for phase II of the Trials of Hypertension Prevention. Effective strategies and predictors of randomization. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5:140-148. [pmid: 7795832].
Holm LE, Nordevang E, Ikkala E, et al. Dietary intervention as adjuvant therapy in breast cancer patients -- a feasibility study. Breast Cancer Res Treatment. 1990;16:103-109.
Holme I. An analysis of randomized trials evaluating the effect of cholesterol reduction on total mortality and coronary heart disease incidence. Circulation. 1990;82:1916-1924. [pmid: 2242517].
Hooyman N. Long-Term Outcome Effectiveness of a Health Promotion Program for the Elderly: The Wallingford Wellness Project. Seattle, WA: University of Washington, Institute on Aging and Pacific Northwest Long-Term Care Center; 1984.
Horrocks PM, Blackmore R, Wright AD. A long-term follow-up of dietary advice in maturity onset diabetes: the experience of one centre in the UK prospective study. Diabetic Med. 1987;4:241-244. [pmid: 2956027].
Horton J. Selection of participants for clinical trials in cancer prevention. Seminars in Oncol. 1983;10:348-354. [pmid: 6665561].
Houston MC. Sodium and hypertension: A review [review]. Arch Intern Med. 1986;146:179-185. [pmid: 3510595].
Hu JJ, Roush GC, Berwick M, et al. Effects of dietary supplementation of alpha-tocopherol on plasma glutathione and DNA repair activities. Cancer Epidemiol, Biomarkers Prev. 1996;5:263-270. [pmid: 8722217].
Huijbregts PP, Feskens EJ, Kromhout D. Dietary patterns and cardiovascular risk factors in elderly men: The Zutphen Elderly Study. Int J Epidemiol. 1995;24:313-320. [pmid: 7635591].
Hutchinson R, McAlack R, Evans A, et al. Inhibition of normal human granulopoiesis by neuroblastoma cells. Am J Pediatr Hematol-Oncol. 1983;5:133-137. [pmid: 6614394].
Huttunen JK. Health effects of supplemental use of antioxidant vitamins: Experiences from the alpha-tocopherol beta-carotene (ATBC) cancer prevention study. Scandinavian Journal of Nutrition/Naringsforskning. 1995;39:103-104.
Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: Three-year effects of dietary changes on blood pressure. Hypertension Prevention Trial Research Group. Arch Internal Med. 1990;150:153-162. [pmid: 2404477].
Inoue Y, Bode BP, Souba WW, et al. Dietary regulation of the hepatic system n glutamine transporter in tumor-bearing rats. Am J Surg. 1995;169:173-178. [pmid: 7817988].
Insull W Jr, Henderson MM, Prentice RL, et al. Results of a randomized feasibility study of a low-fat diet. Arch Intern Med. 1990;150:421-427. [pmid: 2405805].
Ishikawa H, Akedo I, Suzuki T, et al. Interventional trial for colorectal cancer prevention in Osaka: An introduction to the protocol. Jpn J Cancer Res. 1995;86:707-710. [pmid: 7559090].
Iso H, Shimamoto T, Yokota K, et al. Community-based education classes for hypertension control. A 1.5-year randomized controlled trial. Hypertension. 1996;27:968-974. [pmid: 8613276].
Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9:274-281. [pmid: 8257616].
Iwamoto RR. A nursing perspective on radiation-induced xerostomia. Oncology. 1996;10(3 suppl):12-15. [pmid: 8723428].
Jacoby RF, Marshall DJ, Newton MA, et al. Chemoprevention of spontaneous intestinal adenomas in the Apc(Min) mouse model by the nonsteroidal anti-inflammatory drug piroxicam. Cancer Res. 1996;56:710-714. [pmid: 8631000].
Jaycox S, Baranowski T, Nader PR, et al. Theory-based health education activities for third to sixth grade children. J School Health. 1983;53:584-588. [pmid: 6558280].
Jeffery RW, French SA, Schmid TL. Attributions for dietary failures: Problems reported by participants in the Hypertension Prevention Trial. Health Psychol. 1990;9:315-329. [pmid: 2187695].
Jeffery RW, Gillum R, Gerber WM, et al. Weight and sodium reduction for the prevention of hypertension: A comparison of group treatment and individual counseling. Am J Public Health. 1983;73:691-693. [pmid: 6846677].
Jeffery RW, Tonascia S, Bjornson-Benson W, et al. Treatment in the Hypertension Prevention Trial: Hypertension Prevention Trial Research Group. Controlled Clin Trials. 1989;10(3 suppl):65S-83S. [pmid: 2680274].
Jenkin RD, Boesel C, Ertel I, et al. Brain-stem tumors in childhood: A prospective randomized trial of irradiation with and without adjuvant CCNU, VCR, and prednisone -- A report of the Children's Cancer Study Group. J Neurosurg. 1987;66:227-233. [pmid: 3806204].
Jennings GE. Nutritional Care Services for Elderly Subscribers Provided by Health Maintenance Organizations. Pullman, WA: Washington State University, Department of Food and Nutrition, 1980.
Johnston BL, Cantwell JD, Fletcher GF. Eight steps to inpatient cardiac rehabilitation: The team effort-methodology and preliminary results. Heart & Lung. 1976;5:97-111. [pmid: 1043878].
Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. The 1984 Report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. Arch Intern Med. 1984;144:1045-1057. [pmid: 6143542].
Jolly K, Bradley F, Sharp S, et al. Follow-up care in general practice of patients with myocardial infarction or angina pectoris: Initial results of the SHIP trial. Fam Pract. 1998;15:548-555. [pmid: 10078796].
Kaczmarek JC, Kates R, Rau F, et al. Intrapartum uterine rupture in a primiparous patient previously treated for invasive mole. Obstet Gynecol. 1994;83(5 Pt 2):842-844. [pmid: 8159371].
Kahn HS, Williamson DF, Stevens JA. Race and weight change in US women: The roles of socioeconomic and marital status. Am J Public Health. 1991;81:319-323. [pmid: 2036117].
Kaibara A, Yoshida S, Yamasaki K, et al. Effect of glutamine and chemotherapy on protein metabolism in tumor-bearing rats. J Surg Res. 1994;57:143-149. [pmid: 8041129].
Kaiser FE. Cholesterol and the older adult. South Med J. 1993;86:2S11-2S14. [pmid: 8211350].
Kane R, Harvey H, Andrews T, et al. Phase II trial of cyclophosphamide, hexamethylmelamine, adriamycin, and cis-dichlorodiammineplatinum(II) combination chemotherapy in advanced ovarian carcinoma. Cancer Treatment Rep. 1979;63:307-309.
Kaplan NM. Lipid intervention trials in primary prevention: A critical review. Clin Exp Hypertens - Part A, Theory & Practice. 1992;14(1-2):109-118.
Kaplan RM. Health promotion and coronary heart disease: A rejoinder. Am Psychol. 1986;41:98-99.
Kaplan RM, Hartwell SL, Wilson DK, et al. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J General Int Med. 1987;2:220-228.
Karagas MR, Tosteson TD, Greenberg ER, et al. Effects of milk and milk products on rectal mucosal cell proliferation in humans. Cancer Epidemiol, Biomarkers Prev. 1998;7:757-766. [pmid: 9752983].
Katell A, Callahan EJ, Fremouw WJ, et al. The effects of behavioral treatment and fasting on eating behaviors and weight loss: A case study. Behav Therapy. 1979;10:579-587.
Kaur K, Singh MM, Kumar, et al. Knowledge and self-care practices of diabetics in a resettlement colony of Chandigarh. Indian J Med Sci. 1998;52:341-347. [pmid: 9988968].
Keenan DP, Achterberg C, Kris-Etherton PM, et al. Use of qualitative and quantitative methods to define behavioral fat-reduction strategies and their relationship to dietary fat reduction in the Patterns of Dietary Change Study. J Am Diet Assoc. 1996;96:1245-1250, 1253. [pmid: 8948385].
Keith PM, Schafer RB. Correlates of dietary change among younger and older men. J Nutr Elderly. 1997;16:33-46.
Kelder SH, Perry CL, Klepp KI. Community-wide youth exercise promotion: Long-term outcomes of the Minnesota Heart Health Program and the Class of 1989 Study. J School Health. 1993;63:218-223. [pmid: 8336479].
Kelsey KS, Kirkley BG, DeVellis RF, et al. Social support as a predictor of dietary change in a low-income population. Health Educ Res. 1996;11:383-395.
Key TJ, Thorogood M, Appleby PN, et al. Dietary habits and mortality in 11,000 vegetarians and health conscious people: Results of a 17 year follow up. BMJ. 1996;313(7060):775-779. [pmid: 8842068].
Keyserling TC, Ammerman AS, Davis CE, et al. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: The Southeast Cholesterol Project. Arch Fam Med. 1997;6:135-145. [pmid: 9075448].
Khan SA, Evans A. An examination of the chromosomal abnormalities of benign tumors may provide a lead to the identification of "metastasis genes.". Cancer Genetics & Cytogenetics. 1991;54:139-141. [pmid: 2065311].
Killen JD, Robinson TN, Telch MJ, et al. The Stanford Adolescent Heart Health Program. Health Educ Q. 1989;16:263-283. [pmid: 2732068].
Killen JD, Telch MJ, Robinson TN, et al. Cardiovascular disease risk reduction for tenth graders: A multiple-factor school-based approach. JAMA. 1988;260:1728-1733. [pmid: 3411756].
Kilo C, Miller JP, Williamson JR. The crux of the UGDP: Spurious results and biologically inappropriate data analysis. Diabetologia. 1980;18:179-185. [pmid: 6989693].
King AC, Martin JE, Morrell EM, et al. Highlighting specific patient education needs in an aging cardiac population. Health Educ Q. 1986;13:29-38. [pmid: 3485623].
Kinlay S, Heller RF. Effectiveness and hazards of case finding for a high cholesterol concentration. BMJ. 1990;300(6739):1545-1547. [pmid: 2372619].
Kirkman MS, Weinberger M, Landsman PB, et al. A telephone-delivered intervention for patients with NIDDM: Effect on coronary risk factors. Diabetes Care. 1994;17:840-846. [pmid: 7956628].
Kirscht JP, Kirscht JL, Rosenstock IM. A test of interventions to increase adherence to hypertensive medical regimens. Health Educ Q. 1981;8:261-272. [pmid: 7333851].
Kittel FMT, De Backer G, Dramaix M, et al. Education in relation to non-communicable diseases: Present findings from Belgian studies. In: Schmidt LR, ed. Theoretical and Applied Aspects of Health Psychology. London, NY: Harwood Academic Publishers. 1990:103-111. [pmcid: 360717].
Kjelsberg MO, Cutler JA, Dolecek TA. Chapter 2. Brief description of the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65(1 suppl):191S-195S. [pmid: 8988937].
Klahr S, Breyer JA, Beck GJ, et al. Dietary protein restriction, blood pressure control, and the progression of polycystic kidney disease: Modification of Diet in Renal Disease Study Group. J Am Society Nephrol. 1995;5(12):2037-2047.
Knobf MK, Mullen JC, Xistris D, et al. Weight gain in women with breast cancer receiving adjuvant chemotherapy. Oncol Nurs Forum. 1983;10:28-33.
Knudsen I, Jensen OM. Diet and cancer: Regulatory perspectives in Europe. Prog in Clin Biol Res. 1990;347:285-294. [pmid: 2217397].
Knutsen SF, Knutsen R. The Tromso Survey: The Family Intervention study -- the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20:197-212. [pmid: 2057468].
Kornitzer M, Dramaix M, Thilly C, et al. Belgian heart disease prevention project: Incidence and mortality results. Lancet. 1983;1(8333):1066-1070. [pmid: 6133104].
Kostas G. A hypertension diet education program for public health nurses. J Am Diet Assoc. 1980;77:570-574. [pmid: 7430513].
Kostis JB, Rosen RC, Cosgrove NM, et al. Nonpharmacologic therapy improves functional and emotional status in congestive heart failure. Chest. 1994;106:996-1001. [pmid: 7924541].
Kotake K, Koyama Y, Nasu J, et al. Relation of family history of cancer and environmental factors to the risk of colorectal cancer: A case-control study. Jpn J Clin Oncol. 1995;25:195-202. [pmid: 7474407].
Krachler M, Lindschinger M, Eber B, et al. Trace elements in coronary heart disease: Impact of intensified lifestyle modification. Biolog Trace Element Res. 1997;60:175-185.
Krishnaswamy K, Polasa K. Diet, nutrition & cancer -- the Indian scenario. Indian J Med Res. 1995;102:200-209. [pmid: 8675239].
Krihnaswamy K, Prasad MPR, Krihna TP, et al. A case study of nutrient intervention of oral precancerous lesions in India. Eur J Cancer. 1995;31:41-48.
Kristal AR, Beresford SAA, Lazovich D. Assessing change in diet-intervention research. Am J Clin Nutr. 1994;59(1 suppl):185S-189S. [pmid: 8279421].
Kristal AR, Glanz K, Tilley BC, et al. Mediating factors in dietary change: Understanding the impact of a worksite nutrition intervention. Health Educ Behav. 2000;27:112-125. [pmid: 10709796].
Kristal AR, Patterson RE, Glanz K, et al. Psychosocial correlates of healthful diets: Baseline results from the Working Well Study. Prev Med. 1995;24:221-228. [pmid: 7644443].
Kristal AR, Shattuck AL, Bowen DJ, et al. Feasibility of using volunteer research staff to deliver and evaluate a low-fat dietary intervention: The American Cancer Society Breast Cancer Dietary Intervention Project. Cancer Epidemiol, Biomarkers Prev. 1997;6:459-467. [pmid: 9184781].
Kristal AR, White E, Shattuck AL, et al. Long-term maintenance of a low-fat diet: Durability of fat-related dietary habits in the Women's Health Trial. J Am Diet Assoc. 1992;92:553-559. [pmid: 1573135].
Kritchevsky SB. Beta-carotene, carotenoids and the prevention of coronary heart disease. J Nutr. 1999;129:5-8. [pmid: 9915867].
Kulkarni K, Castle G, Gregory R, et al. Nutrition Practice Guidelines for Type 1 Diabetes Mellitus positively affect dietitian practices and patient outcomes. The Diabetes Care and Education Diet Practice Group. J Am Diet Assoc. 1998;98:62-70. [pmid: 9434653].
Kumanyika S. Obesity in black women. Epidemiol Rev. 1987;9:31-50. [pmid: 3315719].
Kumanyika S. Behavioral aspects of intervention strategies to reduce dietary sodium. Hypertension. 1991;17(1 suppl):I190-I195. [pmid: 1987002].
Kumanyika S. Ethnicity and obesity development in children [review]. Ann NY Acad Sci. 1993;699:81-92. [pmid: 8267340].
Kumanyika S. Racial and ethnic issues in diet and cancer epidemiology. Advances in Exp Med Biol. 1994;354:59-70. [pmid: 8067289].
S. Nutrition & health campaign for all women. J Am Diet Assoc. 1995;95:299-300. [pmid: 7860939].
Kumanyika S. Searching for the association of obesity with coronary artery disease. Obes Res. 1995;3:273-275. [pmid: 7627776].
Kumanyika S. Validating dietary guidance. J Am Coll Nutr. 1995;14:215-216. [pmid: 8586767].
Kumanyika S. Improving our diet -- still a long way to go. N Engl J Med. 1996;335:738-740. [pmid: 8703177].
Kumanyika S. Correction and revision of conclusions -- dietary trends in the United States. N Engl J Med. 1997;337(25).
Kumanyika S, Adams-Campbell LL. Obesity, diet, and psychosocial factors contributing to cardiovascular disease in blacks. Cardiovasc Clin. 1991;21:47-73. [pmid: 2044117].
Kumanyika S, Bonner M. Toward a lower-sodium lifestyle in black communities. J Natl Med Assoc. 1985;77:969-975. [pmid: 4078925]. [pmcid: 1064642].
Kumanyika S, Savage DD, Ramirez AG, et al. Beliefs about high blood pressure prevention in a survey of blacks and Hispanics. Am J Prev Med. 1989;5:21-26. [pmid: 2742786].
Kumanyika S, Tell GS, Fried L, et al. Picture-sort method for administering a food frequency questionnaire to older adults. J Am Diet Assoc. 1996;96:137-144. [pmid: 8557939].
Kumanyika S, Tell GS, Shemanski L, et al. Eating patterns of community-dwelling older adults: The Cardiovascular Health Study. Ann Epidemiol. 1994;4:404-415. [pmid: 7981849].
Kumanyika S, Wilson JF, Guilford-Davenport M. Weight-related attitudes and behaviors of black women. J Am Diet Assoc. 1993;93:416-422. [pmid: 8454809].
Kumanyika SK. Can hypertension be prevented? Applications of risk modifications in black populations: U.S. populations. Ethnicity & Dis. 1997;7:72-77.
Kumanyika SK, Bowen D, Rolls BJ, et al. Maintenance of dietary behavior change. Health Psychol. 2000;19:42-56. [pmid: 10709947].
Kumanyika SK, Hebert PR, Cutler JA, et al. Feasibility and efficacy of sodium reduction in the Trials of Hypertension Prevention, phase I. Trials of Hypertension Prevention Collaborative Research Group. Hypertension. 1993;22:502-512. [pmid: 8406655].
Kumanyaka SK, Obarzanek E, Stevens VJ, et al. Weight-loss experience of black and white participants in NHLBI-sponsored clinical trials. Am J Clin Nutr. 1991;53(6 suppl):1631S-1638S. [pmid: 2031498].
Kwiatkowska J, Boguslawska-Jaworska J, Baranowski T. Studies on glycolysis of erythrocytes in childhood anemias. 3. Hemolytic, aplastic, and hypoplastic anemias and reticuloendothelioses. Archivum Immunologiae Et Therapiae Experimentalis. 1968;16:927-934. [pmid: 4236368].
Kwiatkowska J, Zatonski W, Baranowski T. Erythrocyte phosphofructokinase and glucose-6-phosphate dehydrogenase in leukemia. Clinica Chimica Acta. 1973;45:403-408.
Lackey CJ, Kolasa KM, Horner RD. Nutrition education in a community cholesterol screening program. Health Values. 1992;16:39-47.
Lagstrom H, Jokinen E, Seppanen R, et al. Nutrient intakes by young children in a prospective randomized trial of a low-saturated fat, low-cholesterol diet. The STRIP Baby Project. Special Turku Coronary Risk Factor Intervention Project for Babies. Arch Pediatr Adolesc Med. 1997;151:181-188. [pmid: 9041875].
Laitinen JH, Ahola IE, Sarkkinen ES, et al. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93:276-283. [pmid: 8382712].
Lake CR, Zaloga G, Clymer R, et al. A double dose of phenylpropanolamine causes transient hypertension. Am J Med. 1988;85:339-343. [pmid: 3414729].
Lamberg L. Diet may affect skin cancer prevention. JAMA. 1998;279:1427-1428. [pmid: 9600464].
Lambrew JM, DeFriese GH, Carey TS, et al. The effects of having a regular doctor on access to primary care. Med Care. 1996;34:138-151. [pmid: 8632688].
Lange B, Littman P, Schnaufer L, et al. Treatment of advanced Hodgkin's disease in pediatric patients. Cancer. 1978;42:1141-1145. [pmid: 100204].
Lanza E, Schatzkin A, Ballard-Barbash R, et al. The polyp prevention trial II: Dietary intervention program and participant baseline dietary characteristics [published erratum appears in Cancer Epidemiol Biomarkers Prev. 1996 Jul;5(7):584]. Cancer Epidemiol, Biomarkers Prev. 1996;5:385-392. [pmid: 9162305].
Lapinleimu H, Jokinen E, Myyrinmaa A, et al. Individualized dietary counselling of families: Serum cholesterol concentration and growth of children aged 7-13 months. Acta Paediatrica. 1994;83:383-388. [pmid: 8025393].
Laramee LA, Huston P. Current issues in cardiac care. Can Fam Physician. 1998;44:2607-2610, 2617-2620. [pmid: 9870108].
Lasser VI, Raczynski JM, Stevens VJ, et al. Trials of Hypertension Prevention, phase II. Structure and content of the weight loss and dietary sodium reduction interventions. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5:156-164. [pmid: 7795834].
Lee HP. Health benefits and risk analysis with reference to cancer studies [review]. Nutr Rev. 1996;54(11 Pt 2):S141-S142. [pmid: 9110591].
Lee-Han H, Cousins M, Beaton M, et al. Compliance in a randomized clinical trial of dietary fat reduction in patients with breast dysplasia. Am J Clin Nutr. 1988;48:575-586. [pmid: 3046298].
Lee IM. Antioxidant vitamins in the prevention of cancer. Proc Assoc Am Phys. 1999;111:10-15. [pmid: 9893152].
Leikin S, Bernstein I, Evans A, et al. Use of combination adriamycin (NSC-123127) and DTIC (NSC-45388) in children with advanced stage IV neuroblastoma. Cancer Chemotherapy Rep - Part. 1975;59:1015-1018.
Leitha T, Staudenherz A, Bachmann B, et al. Effectiveness of coronary heart disease risk management in high-risk patients. Clin Cardiol. 1994;17:123-130. [pmid: 8168280].
Le Marchand L, Hankin JH, Carter FS, et al. A pilot study on the use of plasma carotenoids and ascorbic acid as markers of compliance to a high fruit and vegetable dietary intervention. Cancer Epidemiol, Biomarkers Prev. 1994;3:245-251. [pmid: 8019375].
Levine DM. Health education for behavioral change -- clinical trial to public health program. Johns Hopkins Med J. 1982;151:215-219. [pmid: 7143873].
Lewis CE, George V, Fouad M, et al. Recruitment strategies in the Women's Health Trial: Feasibility Study in Minority Populations. Controlled Clin Trials. 1998;19:461-476. [pmid: 9741867].
Lewis CE, Grandits A, Flack J, et al. Efficacy and tolerance of antihypertensive treatment in men and women with stage 1 diastolic hypertension. Results of the Treatment of Mild Hypertension Study. Arch Intern Med. 1996;156:377-385. [pmid: 8607723].
Li B, Taylor PR, Li JY, et al. Linxian nutrition intervention trials: Design, methods, participant characteristics, and compliance. Ann Epidemiol. 1993;3:577-585. [pmid: 7921303].
Li J, Kudsk KA, Janu P, et al. Effect of glutamine-enriched total parenteral nutrition on small intestinal gut-associated lymphoid tissue and upper respiratory tract immunity. Surgery. 1997;121:542-549. [pmid: 9142153].
Li JY, Li GY, Zheng SF, et al. A pilot vitamin intervention trial in Linxian, People's Republic of China. Natl Cancer Inst Monogr. 1985:6919-6922.
Li JY, Taylor PR, Li B, et al. Nutrition intervention trials in Linxian, China: Multiple vitamin/mineral supplementation, cancer incidence, and disease-specific mortality among adults with esophageal dysplasia. J Natl Cancer Inst. 1993;85:1492-1498. [pmid: 8360932].
Lian Z, Jun-Ling M, Wei-Dong L. A randomized multi-intervention trial to inhibit gastric cancer in Shandong [progress report]. Chin J Clin Oncol. 1998;25:338-340.
Lidell E, Fridlund B. Long-term effects of a comprehensive rehabilitation programme after myocardial infarction. Scand J Caring Sci. 1996;10:67-74. [pmid: 8717802].
Liede KE, Alfthan G, Hietanen JHP, et al. Beta-carotene concentration in buccal mucosal cells with and without dysplastic oral leukoplakia after long-term beta-carotene supplementation in male smokers. Eur J Clin Nutr. 1998;52:872-876. [pmid: 9881881].
Light L, Contento IR. Changing the course: A school nutrition and cancer education curriculum developed by the American Cancer Society and the National Cancer Institute [review]. J School Health. 1989;59:205-209. [pmid: 2661914].
Lindahl O, Lindwall L, Spangberg A, et al. A vegan regimen with reduced medication in the treatment of hypertension. Br J Nutr. 1984;52:11-20. [pmid: 6743632].
Lindholm LH, Ekbom T, Dash C, et al. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310(6987):1105-1109. [pmid: 7742677].
Lipkin M, Newmark H. Calcium and the prevention of colon cancer. J Cellular Biochemistry. 1995;58(suppl 22):65-73.
Little P, Girling G, Hasler A, et al. A controlled trial of a low sodium, low fat, high fibre diet in treated hypertensive patients: The efficacy of multiple dietary intervention. Postgraduate Med J. 1990;66(778):616-621.
Livingston IL. Blacks, life-style and hypertension: The importance of health education. Humboldt J Soc Relations. 1987;14(1-2):195-213.
Loprinzi CL, Athmann LM, Kardinal CG, et al. Randomized trial of dietician counseling to try to prevent weight gain associated with breast cancer adjuvant chemotherapy. Oncology. 1996;53:228-232. [pmid: 8643226].
Lotan R. Retinoids in cancer chemoprevention. FASEB J. 1996;10:1031-1039. [pmid: 8801164].
Lovibond SH, Birrell PC, Langeluddecke P. Changing coronary heart disease risk-factor status: The effects of three behavioral programs. J Behav Med. 1986;9:415-437. [pmid: 3540308].
Luc G, Bard JM, Arveiler D, et al. Impact of apolipoprotein E polymorphism on lipoproteins and risk of myocardial infarction: The ECTIM Study. Arterioscl Thromb. 1994;14:1412-1419. [pmid: 8068601].
Luc G, Ducimetiere P, Bard JM, et al. Distribution of apolipoprotein E between apo B- and non apo B-containing lipoproteins according to apo E phenotype. Atherosclerosis. 1997;131:257-262. [pmid: 9199280].
Luepker RV, Perry CL, McKinlay SM, et al. Outcomes of a field trial to improve children's dietary patterns and physical activity. The Child and Adolescent Trial for Cardiovascular Health. CATCH collaborative group. JAMA. 1996;275:768-776. [pmid: 8598593].
Luepker RV, Perry CL, Murray DM, et al. Hypertension prevention through nutrition education in youth: A school-based program involving parents. Health Psychol. 1988;7(suppl):233-245. [pmid: 3243221].
Luft FC, Morris CD, Weinberger MH. Compliance to a low-salt diet [review]. Am J Clin Nutr. 1997;65(2 Suppl):698S-703S. [pmid: 9022568].
Lutz SF, Ammerman AS, Atwood JR, et al. Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99:705-709. [pmid: 10361533].
Lye M, Valacio R, Reckless JPD, et al. Elderly patients with hypercholesterolaemia: A double-blind study of the efficacy, safety and tolerability of fluvastatin. Coronary Artery Dis. 1998;9:583-590.
Lytle LA, Stone EJ, Nichaman MZ, et al. Changes in nutrient intakes of elementary school children following a school-based intervention: Results from the CATCH Study. Prev Med. 1996;25:465-477. [pmid: 8818069].
Macaulay AC, Paradis G, Potvin L, et al. The Kahnawake Schools Diabetes Prevention Project: Intervention, evaluation, and baseline results of a diabetes primary prevention program with a native community in Canada. Prev Med. 1997;26:779-790. [pmid: 9388789].
Maccoby N, Farquhar JW, Fortmann SP, Kaplan RM. Disease Prevention Program; NATO ASI series A. Life Sciences. 1985;84:385-400.
MacGregor GA, Markandu ND, Sagnella GA, et al. Double-blind study of three sodium intakes and long-term effects of sodium restriction in essential hypertension. Lancet. 1989;2(8674):1244-1247. [pmid: 2573761].
MacKie RM, Hole D, Hunter JA, et al. Cutaneous malignant melanoma in Scotland: Incidence, survival, and mortality, 1979-94 (The Scottish Melanoma Group). BMJ. 1997;315(7116):1117-1121. [pmid: 9374883].
MacLennan R. Diet and colorectal cancer. Int J Cancer. 1997;72(suppl):10-12. [pmid: 9209013].
MacLennan R, Macrae F, Bain C, et al. Randomized trial of intake of fat, fiber, and beta carotene to prevent colorectal adenomas. J Natl Cancer Inst. 1995;87(23):1760-1766. [pmid: 7473832].
MacMahon S, Sharpe N, Gamble G, et al. Effects of lowering average or below-average cholesterol levels on the progression of carotid atherosclerosis: Results of the lipid atherosclerosis substudy. Circulation. 1998;97:1784-1790. [pmid: 9603532].
Macrae F. Wheat bran fiber and development of adenomatous polyps: Evidence from randomized, controlled clinical trials. Am J Med. 1999;106(1 A):38S-42S. [pmid: 10089114].
Macrae FA. Fat and calories in colon and breast cancer: From animal studies to controlled clinical trials. Prev Med. 1993;22:750-766. [pmid: 8234215].
Madsen J, Sallis JF, Rupp JW, et al. Process variables as predictors of risk factor changes in a family health behavior change program. Health Educ Res. 1993;8:193-204. [pmid: 10148828].
Madsen J, Sallis JF, Rupp JW, et al. Relationship between self-monitoring of diet and exercise change and subsequent risk factor changes in children and adults. Patient Educ Counseling. 1993;21(1-2):61-69.
Malinow MR, Duell PB, Hess DL, et al. Reduction of plasma homocyst(e)ine levels by breakfast cereal fortified with folic acid in patients with coronary heart disease. N Engl J Med. 1998;338:1009-1015. [pmid: 9535664].
Mannick EE, Bravo LE, Zarama G, et al. Inducible nitric oxide synthase, nitrotyrosine, and apoptosis in Helicobacter pylori gastritis: Effect of antibiotics and antioxidants. Cancer Res. 1996;56(14):3238-3243. [pmid: 8764115].
Manson JE, Buring JE, Satterfield S, et al. Baseline characteristics of participants in the Physicians' Health Study: A randomized trial of aspirin and beta-carotene in U.S. physicians. Am J Prev Med. 1991;7:150-154. [pmid: 1931143].
Manttari M, Elo O, Frick MH, et al. The Helsinki heart study: Basic design and randomization procedure. Eur Heart J. 1987;8(suppl I):1-29.
Marchioli R, Marfisi RM, Carinci F, et al. Meta-analysis, clinical trials, and transferability of research results into practice: The case of cholesterol-lowering interventions in the secondary prevention of coronary heart disease. Arch Intern Med. 1996;156:1158-1172. [pmid: 8639010].
Marckmann P, Bladbjerg EM, Jespersen J. Dietary fish oil (4 g daily) and cardiovascular risk markers in healthy men. Arterioscl Thromb Vascular Biol. 1997;17(12):3384-3391.
Marcus AC, Heimendinger J, Wolfe P, et al. Increasing fruit and vegetable consumption among callers to the CIS: Results from a randomized trial. Prev Med. 1998;27(5 Pt 2):S16-S28. [pmid: 9808821].
Marcus AC, Morra M, Rimer BK, et al. A feasibility test of a brief educational intervention to increase fruit and vegetable consumption among callers to the Cancer Information Service. Prev Med. 1998;27:250-261. [pmid: 9579004].
Mark SD, Wang W, Fraumeni JF Jr, et al. Do nutritional supplements lower the risk of stroke or hypertension?. Epidemiology. 1998;9:9-15. [pmid: 9430262].
Marques-Vidal P, Cambou JP, Nicaud V, et al. Cardiovascular risk factors and alcohol consumption in France and Northern Ireland. Atherosclerosis. 1995;115:225-232. [pmid: 7661881].
Marques-Vidal P, Ducimetiere P, Evans A, et al. Alcohol consumption and myocardial infarction: A case-control study in France and Northern Ireland [comment]. Am J Epidemiol. 1996;143:1089-1093. [pmid: 8633596].
Vazquez Martinez C, Galan P, Preziosi P, et al. Survey SUVIMAX (France): The role of antioxidants in the prevention of cancer and cardiovascular disease. Consciousness & Cogn. 1998;72:173-183.
Martinez ME, Reid ME, Guillen-Rodriguez J, et al. Design and baseline characteristics of study participants in the Wheat Bran Fiber trial. Cancer Epidemiol, Biomarkers Prev. 1998;7:813-816. [pmid: 9752991].
Martini MC, Campbell DR, Gross MD, et al. Plasma carotenoids as biomarkers of vegetable intake: The University of Minnesota cancer prevention research unit feeding studies. Cancer Epidemiol, Biomarkers Prev. 1995;4:491-496. [pmid: 7549804].
Mason B, Matsuyama J, Jue S. Adherence consistency across treatment regimens [letter]. Diabetes Care. 1994;17:347-348. [pmid: 8026296].
Mavroudis K, Evans A, Mamtora H, et al. Bioactive LH in women with polycystic ovaries and the effect of gonadotrophin suppression. Clin Endocrinol. 1988;29:633-641.
Mayeda C, Anderson J. Evaluating the effectiveness of the 'Self-CARE for a Healthy Heart' program with older adults. J Nutr Elderly. 1993;13(2):11-22.
Mayne ST, Cartmel B, Silva F, et al. Effect of supplemental beta-carotene on plasma concentrations of carotenoids, retinol, and alpha-tocopherol in humans. Am J Clin Nutr. 1998;68:642-647. [pmid: 9734742].
McArthur DB. Heart healthy eating behaviors of children following a school-based intervention: A meta-analysis. Issues in Compr Pediatr Nurs. 1998;21:35-48.
McCann BS, Bovbjerg VE. Promoting dietary change. In: Shumaker SA, Schron EB (eds.). The Handbook of Health Behavior and Change. 2d ed. New York, NY: Springer Publishing. 1998:166-188. [pmcid: 325543].
McClean R, McCrum E, Scally G, et al. Dietary patterns in the Belfast MONICA Project. Proc Nutr Soc. 1990;49:297-305. [pmid: 2236094].
McCullum C, Achterberg CL. Food shopping and label use behavior among high school-aged adolescents. Adolescence. 1997;32(125):181-197. [pmid: 9105500].
McGowan MP, Joffe A, Duggan AK, et al. Intervention in hypercholesterolemic college students: A pilot study. J Adolescent Health. 1994;15:155-162.
McKeigue P. Diets for secondary prevention of coronary heart disease: Can linolenic acid substitute for oily fish?. Lancet. 1994;343(8911).
McKeown-Eyssen GE, Bright-See E, Bruce WR, et al. A randomized trial of a low fat high fibre diet in the recurrence of colorectal polyps. J Clin Epidemiol. 1994;47:525-536. [pmid: 7730878].
McKinlay JB. A case for re-focusing upstream: The political economy of illness. In: Enelow AJ, Henderson JB, eds. Applying Behavioral Science to Cardiovascular Risk. Seattle, WA: American Heart Association. 1975:7-18. [pmcid: 186900].
McKinlay JB. The new public health approach to improving physical activity and autonomy in older populations. In: Heikkinen E, ed. Preparation for Aging. New York, NY: Plenum Press. 1995:87-103. [pmcid: 167263].
Meinert CL, Borhani NO, Langford HG. Design, methods, and rationale in the Hypertension Prevention Trial. Hypertension Prevention Trial Research Group. Controlled Clin Trials. 1989;10(3 suppl):1S-29S. [pmid: 2680271].
Meland E, Laerum E, Ulvik RJ. Salt restriction in hypertension -- the effect of dietary advice and self monitoring of chloride concentration in urine. Scand J Clin Lab Invest. 1994;54:399-404. [pmid: 7997845].
Meland E, Laerum E, Ulvik RJ. Effectiveness of two preventive interventions for coronary heart disease in primary care. Scand J Primary Health Care. 1997;15:57-64.
Merz CNB, Rozanski A, Forrester JS. The secondary prevention of coronary artery disease. Am J Med. 1997;102:572-581. [pmid: 9217673].
Mettlin C. Dietary cancer prevention in children. Cancer. 1993;71(10 suppl):3367-3369. [pmid: 8490884].
Mettlin C. Chemoprevention: Will it work?. Int J Cancer. 1997;72(suppl):18-21. [pmid: 9209015].
Mettlin C, Cummings KM, Walsh D. Risk factor and behavioral correlates of willingness to participate in cancer prevention trials. Nutr Cancer. 1985;7:189-198. [pmid: 3834402].
Metz JA, Kris-Etherton PM, Morris CD, et al. Dietary compliance and cardiovascular risk reduction with a prepared meal plan compared with a self-selected diet. Am J Clin Nutr. 1997;66:373-385. [pmid: 9250117].
Metzner HL, Carman WJ, House J. Health practices, risk factors, and chronic disease in Tecumseh. Prev Med. 1983;12:491-507. [pmid: 6622434].
Meydani M, Meisler JG. A closer look at vitamin E: Can this antioxidant prevent chronic diseases?. Postgraduate Med. 1997;102:199-207.
Mielenz TJ, Carey TS, Dyrek DA, et al. Physical therapy utilization by patients with acute low back pain. Physical Therapy. 1997;77:1040-1051. [pmid: 9327819].
Miettinen TA, Huttunen JK, Naukkarinen V, et al. Multifactorial primary prevention of cardiovascular diseases in middle-aged men: Risk factor changes, incidence, and mortality. JAMA. 1985;254:2097-2102. [pmid: 4046137].
Milani RV, Lavie CJ. Pharmacologic prevention of coronary artery disease: What do clinical trials show?. Postgraduate Med. 1996;99:109-112, 115-116, 118-120.
Miller AB, Berrino F, Hill M, et al. Diet in the aetiology of cancer: A review. Eur J Cancer. 1994;30:207-220.
Miller C, Warland R, Achterberg C. Food purchase decision-making typologies of women with non-insulin-dependent diabetes mellitus. Patient Educ Counseling. 1997;30:271-281.
Miller CK, Jensen GL, Achterberg CL. Evaluation of a food label nutrition intervention for women with type 2 diabetes mellitus. J Am Diet Assoc. 1999;99:323-328. [pmid: 10076584].
Miller CK, Probart CK, Achterberg CL. Knowledge and misconceptions about the food label among women with non-insulin-dependent diabetes mellitus. Diabetes Educator. 1997;23:425-432. [pmid: 9305008].
Miller DB. Secondary prevention for ischemic heart disease: Relative numbers needed to treat with different therapies. Arch Intern Med. 1997;157:2045-2052. [pmid: 9382659].
Miller P, Johnson NL, Garrett MJ, et al. Health beliefs of and adherence to the medical regimen by patients with ischemic heart disease. Heart & Lung. 1982;11:332-339. [pmid: 6919529].
Miller P, Wikoff R, Garrett MJ, et al. Regimen compliance two years after myocardial infarction. Nurs Res. 1990;39:333-336. [pmid: 2092306].
Miller P, Wikoff RL, McMahon M, et al. Indicators of medical regimen adherence for myocardial infarction patients. Nurs Res. 1985;34:268-272. [pmid: 3850486].
Miller P, Wikoff R, McMahon M, et al. Influence of a nursing intervention on regimen adherence and societal adjustments postmyocardial infarction. Nurs Res. 1988;37:297-302. [pmid: 3047691].
Mittelmark MB, Luepker RV, Jacobs DR, et al. Community-wide prevention of cardiovascular disease: Education strategies of the Minnesota Heart Health Program. Prev Med. 1986;15:1-17. [pmid: 3714655].
Monnin S, Schiller MR, Sachs L, et al. Nutritional concerns of women with breast cancer. J Cancer Educ. 1993;8:63-69. [pmid: 8489912].
Morabia A, Bernstein M, Kumanyika S, et al. Development and validation of a semi-quantitative food questionnaire based on a population survey [in French]. Sozial- Und Praventivmedizin. 1994;39:345-369. [pmid: 7817624].
Morabia A, Bernstein M, Ross A, et al. Dietary intake of total lipids and saturated fatty acids of the Geneva population: An unexpected development [in French]. Sozial- Und Praventivmedizin. 1993;38:202-205. [pmid: 8212909].
Morssink CB, Kumanyika S, Tell GS, et al. Recruiting minorities into the profession of epidemiology: Surveying the applicants' mail. American College of Epidemiology Committee on Minority Affairs. Ann Epidemiol. 1996;6:4-11. [pmid: 8680623].
Moser M. A decade of progress in the management of hypertension. Hypertension. 1983;5:808-813. [pmid: 6360867].
Mouzas IA, Papavassiliou E, Koutroubakis I. Chemoprevention of colorectal cancer in inflammatory bowel disease? A potential role for folate. Italian J Gastroenterol Hepatol. 1998;30:421-425.
Mueller N, Evans A, Harris NL, et al. Hodgkin's disease and Epstein-Barr virus: Altered antibody pattern before diagnosis. N Engl J Med. 1989;320:689-695. [pmid: 2537928].
Mueller N, Mohar A, Evans A, et al. Epstein-Barr virus antibody patterns preceding the diagnosis of non-Hodgkin's lymphoma. Int J Cancer. 1991;49:387-393. [pmid: 1655660].
Mueller NE, Mohar A, Evans A. Viruses other than HIV and non-Hodgkin's lymphoma. Cancer Res. 1992;52(19 suppl):5479s-5481s. [pmid: 1394158].
Murray DM, Kurth C, Mullis R, et al. Cholesterol reduction through low-intensity interventions: Results from the Minnesota Heart Health Program. Prev Med. 1990;19:181-189. [pmid: 2359741].
Murray DM, Luepker RV, Pirie PL, et al. Systematic risk factor screening and education: A community-wide approach. Prev Med. 1986;15:661-672. [pmid: 3797397].
Myers RE, Vernon SW, Tilley BC, et al. Intention to screen for colorectal cancer among white male employees. Prev Med. 1998;27:279-287. [pmid: 9579008].
Nader PR, Baranowski T, Vanderpool NA, et al. The family health project: Cardiovascular risk reduction education for children and parents. J Dev Behav Pediatr. 1983;4:3-10. [pmid: 6833501].
Nader PR, Sallis JF, Patterson TL, et al. A family approach to cardiovascular risk reduction: Results from the San Diego Family Health Project. Health Educ Q. 1989;16:229-244. [pmid: 2732065].
Nader PR, Sallis JF, Rupp J, et al. San Diego family health project: Reaching families through the schools. J School Health. 1986;56:227-231. [pmid: 3638441].
Nader PR, Sellers DE, Johnson CC, et al. The effect of adult participation in a school-based family intervention to improve children's diet and physical activity: The child and adolescent trial for cardiovascular health. Prev Med. 1996;25:455-464. [pmid: 8818068].
Nader PR, Stone EJ, Lytle LA, et al. Three-year maintenance of improved diet and physical activity: The CATCH cohort. Child and Adolescent Trial for Cardiovascular Health. Arch Pediatr Adolesc Med. 1999;153:695-704. [pmid: 10401802].
Nash JD, Curry S. Vulvar cancer. Surg Oncol Clin North Am. 1998;7:335-346.
Naslund GK, Fredrikson M, Hellenius ML, et al. Characteristics of participating and nonparticipating men in a randomized, controlled diet and exercise intervention trial. Scand J Primary Health Care. 1994;12:249-254.
Naslund GK, Fredrikson M, Hellenius ML, et al. Determinants of compliance in men enrolled in a diet and exercise intervention trial: A randomized, controlled study. Patient Educ Counseling. 1996;29:247-256.
Naslund GK, Fredrikson M, Hellenius ML, et al. Effect of diet and physical exercise intervention programmes on coronary heart disease risk in smoking and non-smoking men in Sweden. J Epidemiol Community Health. 1996;50:131-136. [pmid: 8762375].
Summary of the second report of the National Cholesterol Education Program (NCEP) expert panel on detection, evaluation, and treatment of high blood cholesterol in adults (adult treatment panel II). JAMA. 1993;269:3015-3023. [pmid: 8501844].
Natow AB, Heslin JA, Natow AJ. Nutritional Care of the Older Adult. New York, NY: Macmillan Publishing Company; 1986.
Nattiv A, Puffer JC, Green GA. Lifestyles and health risks of collegiate athletes: A multi-center study. Clin J Sport Med. 1997;7:262-272. [pmid: 9397325].
Neaton JD, Grimm RH Jr, Prineas RJ, et al. Treatment of mild hypertension study: Final results. JAMA. 1993;270:713-724. [pmid: 8336373].
Neighbor WEJ, Scott CS, Schaad DC, et al. Assessment and counseling of coronary risk factors by family practice residents. J Fam Pract. 1991;32:273-281. [pmid: 2002318].
Nelson NJ. Whatever happened to ...?: A 10-year retrospective. J Natl Cancer Inst. 1999;91:114-117. [pmid: 9923851].
Nesbit M, Chard R, Evans A, et al. Evaluation of intramuscular versus intravenous administration of L-asparaginase in childhood leukemia. Am J Pediatr Hematol-Oncol. 1979;1:9-13. [pmid: 295576].
Neugut AI, Jacobson JS, Sherif G, et al. Coronary artery disease and colorectal neoplasia. Dis Colon & Rectum. 1995;38:873-877.
Neutze J, Cormack B, Kerr B, et al. Contribution of a risk factor clinic to lipid management in patients with coronary artery disease. NZ Med J. 1992;105(930):97-99.
Newens AJ, McColl E, Bond S. Changes in reported dietary habit and exercise levels after an uncomplicated first myocardial infarction in middle-aged men. J Clin Nurs. 1997;6:153-160. [pmid: 9188354].
Neyses L, Dorst K, Michaelis J, et al. Compliance with salt restriction as a limiting factor in the primary prevention of hypertension. J Hypertension - Supplement. 1985;3:S87-S90.
Nicklas TA, Dwyer J, Mitchell P, et al. Impact of fat reduction on micronutrient density of children's diets: The CATCH Study. Prev Med. 1996;25:478-485. [pmid: 8818070].
Nicklas TA, Johnson CC, Myers L, et al. Outcomes of a high school program to increase fruit and vegetable consumption: Gimme 5 -- a fresh nutrition concept for students. J School Health. 1998;68:248-253. [pmid: 9719999].
Niebauer J, Hambrecht R, Marburger C, et al. Impact of intensive physical exercise and low-fat diet on collateral vessel formation in stable angina pectoris and angiographically confirmed coronary artery disease. Am J Cardiol. 1995;76:771-775. [pmid: 7572652].
Niebauer J, Hambrecht R, Schlierf G, et al. Five years of physical exercise and low fat diet: Effects on progression of coronary artery disease. J Cardiopulmonary Rehabil. 1995;15:47-64. [pmid: 8529087].
Nierenberg DW, Dain BJ, Mott LA, et al. Effects of 4 y of oral supplementation with beta-carotene on serum concentrations of retinol, tocopherol, and five carotenoids. Am J Clin Nutr. 1997;66:315-319. [pmid: 9250109].
Nierenberg DW, Nann SL. A method for determining concentrations of retinol,tocopherol, and five carotenoids in human plasma and tissue samples. Am J Clin Nutr. 1992;56:417-426. [pmid: 1636620].
Niinikoski H, Koskinen P, Punnonen K, et al. Intake and indicators of iron and zinc status in children consuming diets low in saturated fat and cholesterol: The STRIP baby study. Am J Clin Nutr. 1997;66:569-574. [pmid: 9280175].
Niinikoski H, Viikari J, Ronnemaa T, et al. Prospective randomized trial of low-saturated-fat, low-cholesterol diet during the first 3 years of life: The STRIP baby project. Circulation. 1996;94:1386-1393. [pmid: 8822997].
Nikolaus T, Schlierf G, Vogel G, et al. Treatment of coronary heart disease with diet and exercise: Problems of compliance. Ann Nutr Metab. 1991;35:1-7.
Nilsson J, Ericsson CG, Hamsten A, et al. Bezafibrate following acute myocardial infarction: Important findings from the Bezafibrate Coronary Atherosclerosis Intervention Trial. Fibrinolysis & Proteolysis. 1997;11(suppl 1):159-162.
Nobusawa S, Endo M. Prophylaxis of postoperative biliary stasis: a retrospective and prospective study. Am J Gastroenterol. 1988;83:46-54. [pmid: 3122559].
Noel PH, Larme AC, Meyer J, et al. Patient choice in diabetes education curriculum. Nutritional versus standard content for type 2 diabetes. Diabetes Care. 1998;21:896-901. [pmid: 9614604].
Nordevang E, Callmer E, Marmur A, et al. Dietary intervention in breast cancer patients: Effects on food choice. Eur J Clin Nutr. 1992;46:387-396. [pmid: 1639046].
Nordevang E, Ikkala E, Callmer E, et al. Dietary intervention in breast cancer patients: Effects on dietary habits and nutrient intake. Eur J Clin Nutr. 1990;44:681-687. [pmid: 2261900].
Nugent CA, Carnahan JE, Sheehan ET, et al. Salt restriction in hypertensive patients: Comparison of advice, education, and group management. Arch Intern Med. 1984;144:1415-1417. [pmid: 6732403].
Ockene IS, Merriam PA, Hebert JR, et al. Effect of training and a structured office practice on physician-delivered nutrition counseling: The Worcester-area trial for counseling in hyperlipidemia (WATCH). Am J Prev Med. 1996;12:252-258. [pmid: 8874688].
Olendzki MC, Tolpin HG, Buckley EL. Evaluating nutrition intervention in atherosclerosis: Some theoretical and practical considerations. J Am Diet Assoc. 1981;79:9-16. [pmid: 6787103].
Oliver MF. Prevention of coronary heart disease-propaganda, promises, problems, and prospects. Circulation. 1986;73:1-9. [pmid: 3510083].
Oliver MF. It is more important to increase the intake of unsaturated fats than to decrease the intake of saturated fats: Evidence from clinical trials relating to ischemic heart disease [review]. Am J Clin Nutr. 1997;66(4 suppl):980S-986S. [pmid: 9322577].
Omenn GS. Interpretations of the Linxian vitamin supplement chemoprevention trials. Epidemiology. 1998;9:1-4. [pmid: 9430258].
Omenn GS, Goodman GE, Thornquist MD, et al. Risk factors for lung cancer and for intervention effects in CARET, the beta-carotene and retinol efficacy trial. J Natl Cancer Inst. 1996;88:1550-1559. [pmid: 8901853].
Omura GA, Bundy BN, Berek JS, et al. Randomized trial of cyclophosphamide plus cisplatin with or without doxorubicin in ovarian carcinoma: A gynecologic oncology group study. J Clin Oncol. 1989;7:457-465. [pmid: 2926470].
Orleans CT. Promoting the maintenance of health behavior change: Recommendations for the next generation of research and practice. Health Psychol. 2000;19:76-83. [pmid: 10709951].
Ornish D. Avoiding revascularization with lifestyle changes: The Multicenter Lifestyle Demonstration Project. Am J Cardiol. 1998;82(10B):72T-76T. [pmid: 9671012].
Ornish D, Brown SE, Scherwitz LW, et al. Can lifestyle changes reverse coronary heart disease? The Lifestyle Heart Trial. Lancet. 1990;336(8708).
Ornish D, Scherwitz LW, Billings JH, et al. Intensive lifestyle changes for reversal of coronary heart disease. JAMA. 1998;280:2001-2007. [pmid: 9863851].
Osganian SK, Ebzery MK, Montgomery DH, et al. Changes in the nutrient content of school lunches: Results from the CATCH Eat Smart Food service intervention. Prev Med. 1996;25:400-412. [pmid: 8818064].
Oshaug A, Helle Bjonnes C, Bugge KH, et al. Nutrition promotion and dietary change at off-shore oil installations in the Norwegian sector of the North Sea. Eur J Clin Nutr. 1995;49:883-896. [pmid: 8925790].
Ostwald SK. Changing employees' dietary and exercise practices: An experimental study in a small company. J Occup Med. 1989;31:90-97. [pmid: 2709166].
Otero-Sabogal R, Sabogal F, Perez-Stable EJ, et al. Dietary practices, alcohol consumption, and smoking behavior: Ethnic, sex, and acculturation differences. J Natl Cancer Inst Monogr. 1995;(18):73-82. [pmid: 8562225].
Ovesen L, Allingstrup L, Hannibal J, et al. Effect of dietary counseling on food intake, body weight, response rate, survival, and quality of life in cancer patients undergoing chemotherapy: A prospective, randomized study. J Clin Oncol. 1993;11:2043-2049. [pmid: 8410128].
Pannbacker B, Berkson D, Pardo E, et al. Fat-modified menu's ongoing success noted. Hospitals. 1980;54:95, 97-100.
Parcel GS, Simons-Morton B, O'Hara NM, et al. School promotion of healthful diet and physical activity: Impact on learning outcomes and self-reported behavior. Health Educ Q. 1989;16:181-199. [pmid: 2732062].
Parham DM, Evans A. Pleomorphic adenoma of the breast; a potential for the misdiagnosis of malignancy on fine needle aspiration (FNA). Cytopathology. 1998;9:343-348. [pmid: 9800133].
Patterson RE, Kristal AR, White E. Do beliefs, knowledge, and perceived norms about diet and cancer predict dietary change?. Am J Public Health. 1996;86:1394-1400. [pmid: 8876507].
Patterson TL, Sallis JF, Nader PR, et al. Direct observation of physical activity and dietary behaviors in a structured environment: Effects of a family-based health promotion program. J Behav Med. 1988;11:447-458. [pmid: 3070048].
Patterson TL, Sallis JF, Nader PR, et al. Familial similarities of changes in cognitive, behavioral, and physiological variables in a cardiovascular health promotion program. J Pediatr Psychol. 1989;14(2).
Peiss B, Kurleto B, Rubenfire M. Physicians and nurses can be effective educators in coronary risk reduction. J Gen Intern Med. 1995;10:77-81. [pmid: 7730943].
Peng YM, Peng YS, Lin Y, et al. Concentrations and plasma-tissue-diet relationships of carotenoids, retinoids, and tocopherols in humans. Nutr Cancer. 1995;23:233-246. [pmid: 7603884].
Perry CL, Bishop DB, Taylor G, et al. Changing fruit and vegetable consumption among children: The 5-a-Day Power Plus program in St. Paul, Minnesota. Am J Public Health. 1998;88:603-609. [pmid: 9551002]. [pmcid: 1508423].
Perry CL, Lytle LA, Feldman H, et al. Effects of the Child and Adolescent Trial for Cardiovascular Health (CATCH) on fruit and vegetable intake. J Nutr Educ. 1998;30:354-360. [pmid: 9532074].
Pesce AJ, Phillips TM, Ooi BS, et al. Immune complexes in transitional cell carcinoma. J Urology. 1980;123:486-488.
Petersen LA, Daley J. General internal medicine. JAMA. 1996;275:1811-1812. [pmid: 8642723].
Petrilli ES, Twiggs LB, Blessing JA, et al. Single-dose actinomycin-D treatment for nonmetastatic gestational trophoblastic disease: A prospective phase II trial of the Gynecologic Oncology Group. Cancer. 1987;60(9):2173-2176. [pmid: 2449942].
Petty R, Evans A, Duncan I, et al. Drug resistance in ovarian cancer: The role of p53. Pathol Oncol Res. 1998;4:97-102. [pmid: 9654593].
Pierce JP, Faerber S, Wright FA, et al. Feasibility of a randomized trial of a high-vegetable diet to prevent breast cancer recurrence. Nutr Cancer. 1997;28:282-288. [pmid: 9343838].
Pietinen P, Ascherio A, Korhonen P, et al. Intake of fatty acids and risk of coronary heart disease in a cohort of Finnish men: The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Am J Epidemiol. 1997;145:876-887. [pmid: 9149659].
Pietinen P, Rimm EB, Korhonen P, et al. Intake of dietary fiber and risk of coronary heart disease in a cohort of Finnish men: The Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Circulation. 1996;94:2720-2727. [pmid: 8941095].
Pluschke G, Vanek M, Evans A, et al. Molecular cloning of a human melanoma-associated chondroitin sulfate proteoglycan. Proc NAS United States of America. 1996;93:9710-9715. [pmid: 8790396]. [pmcid: 38494].
Posner BM. Nutrition education for older Americans: National policy recommendations. J Am Diet Assoc. 1982;80:455-458.
Powell AJ, Lyons MK, Rumph JW, et al. Health risk appraisal and serum cholesterol nutrition education: An outcome study. Military Med. 1996;161:70-74. [pmid: 8857216].
Prescott LM. Highlights of the 69th Scientific Sessions of the American Heart Association. P & T. 1997;22:99-101.
Quinn TJ, Jenkins M. Nutritional profiles of selected college females in a 15-week exercise and weight-control class. Health Values. 1991:1534-1541.
Racelis MC, Lombardo K, Verdin J. Impact of telephone reinforcement of risk reduction education on patient compliance. J Vascular Nurs. 1998;16:16-20.
Rackoff WR, Weiman M, Jakobowski D, et al. A randomized, controlled trial of the efficacy of a heparin and vancomycin solution in preventing central venous catheter infections in children. J Pediatr. 1995;127:147-151. [pmid: 7608801].
Rakic V, Puddey IB, Burke V, et al. Influence of pattern of alcohol intake on blood pressure in regular drinkers: A controlled trial. J Hypertension. 1998;16:165-174.
Ramsay LE, Ramsay MH, Hettiarachchi J, et al. Weight reduction in a blood pressure clinic. Br Med J. 1978;2(6132).
Ramsden VR, Shuaib A, Reeder BA, et al. Risk factor awareness: A randomized telephone survey of public knowledge. Can J Public Health. 1994;85:S57-S60. [pmid: 7804953].
Randall E, Marshall JR, Graham S, et al. High-risk health behaviors associated with various dietary patterns. Nutr Cancer. 1991;16:135-151. [pmid: 1796009].
Raney B, Evans A, Granowetter L, et al. Nonsurgical management of children with recurrent or unresectable fibromatosis. Pediatrics. 1987;79:394-398. [pmid: 3103093].
Rankinen T, Rauramaa R, Vaisanen S, et al. Blood coagulation and fibrinolytic factors are unchanged by aerobic exercise or fat modified diet: Randomized clinical trial in middle-aged men. Fibrinolysis. 1994;8:48-53.
Rao AV, Agarwal S. Bioavailability and in vivo antioxidant properties of lycopene from tomato products and their possible role in the prevention of cancer. Nutr Cancer. 1998;31:199-203. [pmid: 9795972].
Rapola JM, Virtamo J, Haukka JK, et al. Effect of vitamin E and beta carotene on the incidence of angina pectoris: A randomized, double-blind, controlled trial. JAMA. 1996;275:693-698. [pmid: 8594266].
Rapola JM, Virtamo J, Ripatti S, et al. Randomised trial of alpha-tocopherol and beta-carotene supplements on incidence of major coronary events in men with previous myocardial infarction. Lancet. 1997;349(9067).
Reid V, Graham I, Hickey N, et al. Factors affecting dietary compliance in coronary patients included in a secondary prevention programme. Human Nutr-Appl Nutr. 1984;38:279-287.
Reid V, Mulcahy R. Nutrient intakes and dietary compliance in cardiac patients: 6-year follow-up. Human Nutr-Appl Nutr. 1987;41:311-318.
Renaud S, de Lorgeril M, Delaye J, et al. Cretan Mediterranean diet for prevention of coronary heart disease. Am J Clin Nutr. 1995;61(6 suppl):1360S-1367S. [pmid: 7754988].
Resbeut M, Marteau P, Cowen D, et al. A randomized double blind placebo controlled multicenter study of mesalazine for the prevention of acute radiation enteritis. Radiotherapy Oncol. 1997;44:59-63.
Resnicow K, Cohn L, Reinhardt J, et al. A 3-year evaluation of the Know Your Body program in inner-city schoolchildren. Health Educ Q. 1992;19:463-480. [pmid: 1452447].
Resnicow K, Davis M, Smith M, et al. Results of the TeachWell worksite wellness program. Am J Public Health. 1998;88:250-257. [pmid: 9491016].
Resnicow K, Davis-Hearn M, Smith M, et al. Social-cognitive predictors of fruit and vegetable intake in children. Health Psychol. 1997;16:272-276. [pmid: 9152706].
Resnicow K, Smith M, Baranowski T, et al. 2-year tracking of children's fruit and vegetable intake. J Am Diet Assoc. 1998;98:785-789. [pmid: 9664920].
Reynolds KD, Franklin FA, Binkley D, et al. Increasing the fruit and vegetable consumption of 4th-graders: Results from the High 5 Project. Prev Med. 2000;30(4):309-19. [pmid: 10731460].
Reynolds KD, Gillum JL, Hyman DJ, et al. Comparing two strategies to modify dietary behavior and serum cholesterol. J Cardiovasc Risk. 1997;4:1-5. [pmid: 9215513].
Reynolds KD, Raczynski JM, Binkley D, et al. Design of 'High 5': A school-based study to promote fruit and vegetable consumption for reduction of cancer risk. J Cancer Educ. 1998;13:169-177. [pmid: 10898562].
Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. 1995;333:1190-1195. [pmid: 7565975].
Rickard KA, Becker MC, Loghmani E, et al. Effectiveness of two methods of parenteral nutrition support in improving muscle mass of children with neuroblastoma or Wilms' tumor. A randomized study. Cancer. 1989;64:116-125. [pmid: 2543492].
Rickard KA, Jaeger Godshall B, Loghmani ES, et al. Integration of nutrition support into oncologic treatment protocols for high and low nutritional risk children with Wilms' tumor. A prospective randomized study. Cancer. 1989;64:491-509. [pmid: 2544254].
Rifkind BM. Diet, cholesterol and coronary heart disease: The Lipid Research Clinics Program [review]. Proc Nutr Soc. 1987;46:367-72. [pmid: 3324096].
Rimer BK. Mammography use in the US: Trends and the impact of interventions. Ann Behav Med. 1995;16(4).
Rimer BK, Glanz K, Lerman C. Contributions of public health to patient compliance. J Community Health. 1991;16:225-240. [pmid: 1918439].
Risberg T, Wist E, Bremnes RM. Patients' opinion and use of non-proven therapies related to their view on cancer aetiology. Anticancer Res. 1998;18(1B):499S-505.
Ritenbaugh C. Dietary supplementation: The case for placebo-controlled trials. Prev Med. 1993;22:667-675. [pmid: 8234206].
Ritenbaugh C, Sampliner R, Aickin M, et al. Risk factors for Barrett's oesophagus: A life history approach to behavioural assessment in the distant past. Eur J Cancer Prev. 1995;4:459-468. [pmid: 8580781].
Robertson I, Bound R, Segal, L. Colorectal cancer, diet and lifestyle factors: Opportunities for prevention. Health Promotion Int. 13:141-150.
Robinson MH, Pye G, Thomas WM, et al. Haemoccult screening for colorectal cancer: The effect of dietary restriction on compliance. Eur J Surg Oncol. 1994;20:545-548. [pmid: 7926056].
Robson WL, Leung AK. Henoch-Schonlein purpura. Adv Pediatr. 1994;41:163-194. [pmid: 7992683].
Roderick P, Ruddock V, Hunt P, et al. A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47:7-12. [pmid: 9115804].
Rodgers AB, Kessler LG, Portnoy B, et al. 'Eat for Health': A supermarket intervention for nutrition and cancer risk reduction. Am J Public Health. 1994;84:72-76. [pmid: 8279615].
Rodriguez GC, Walmer DK, Cline M, et al. Effect of progestin on the ovarian epithelium of macaques: Cancer prevention through apoptosis?. J Soc Gynecol Invest. 1998;5:271-276.
Rose G, Tunstall-Pedoe HD, Heller RF. UK heart disease prevention project: Incidence and mortality results. Lancet. 1983;1(8333):1062-1066. [pmid: 6133103].
Ross JA, Davies SM, Wentzlaff KA, et al. Dietary modulation of serum platelet-derived growth factor-AB levels. Cancer Epidemiol, Biomarkers Prev. 1995;4:485-489. [pmid: 7549803].
Rosser WW. Advising patients about low-fat diets. Can Fam Physician. 1993;39:75-80. [pmid: 8382094].
Roth MJ, Guo-Qing W, Lewin KJ, et al. Histopathologic changes seen in esophagectomy specimens from the high-risk region of Linxian, China: Potential clues to an etiologic exposure?. Hum Pathol. 1998;29(11):1294-1298. [pmid: 9824110].
Routi T, Ronnemaa T, Viikari JS, et al. Tracking of serum lipoprotein (a) concentration and its contribution to serum cholesterol values in children from 7 to 36 months of age in the STRIP Baby Study. Special Turku Coronary Risk Factor Intervention Project for Babies. Ann Med. 1997;29:541-547. [pmid: 9562521].
Runowicz CD. Hormone replacement therapy in cancer survivors: A con opinion. Ca: A Cancer J Clinicians. 1996;46:365-373.
Ryan AJ, Squires S, Strutt HL, et al. Different fates of camptothecin-induced replication fork-associated double-strand DNA breaks in mammalian cells. Carcinogenesis. 1994;15:823-828. [pmid: 8200082].
Sackett DL. How are we to determine whether dietary interventions do more good than harm to hypertensive patients?. Can J Physiol Pharmacol. 1986;64:781-783. [pmid: 3530407].
Sacks FM, Pfeffer MA, Moye' L, et al. Rationale and design of a secondary prevention trial of lowering normal plasma cholesterol levels after acute myocardial infarction: The cholesterol and recurrent events trial (CARE). Am J Cardiol. 1991;68:1436-1446. [pmid: 1746424].
Santamaria L, Bianchi A. Cancer chemoprevention by supplemental carotenoids in animals and humans. Prev Med. 1989;18:603-623. [pmid: 2694158].
Santanello NC, Barber BL, Applegate WB, et al. Effect of pharmacologic lipid lowering on health-related quality of life in older persons: Results from the Cholesterol Reduction in Seniors Program (CRISP) pilot study. J Am Geriatr Soc. 1997;45:8-14. [pmid: 8994481].
Satterfield S, Cutler JA, Langford HG, et al. Trials of hypertension prevention. Phase I design. Ann Epidemiol. 1991;1:455-471. [pmid: 1669525].
Schatzkin A. Dietary change as a strategy for preventing cancer. Cancer & Metastasis Rev. 1997;16:377-392. [pmid: 9433646].
Schatzkin A, Lanza E, Corle D, et al. Lack of effect of a low-fat, high-fiber diet on the recurrence of colorectal adenomas. N Engl J Med. 2000;342:1149-1155. [pmid: 10770979].
Schatzkin A, Lanza E, Freedman LS, et al. The Polyp Prevention Trial I: Rationale, design, recruitment, and baseline participant characteristics. Cancer Epidemiol, Biomarkers Prev. 1996;5:375-383. [pmid: 9162304].
Schectman G, Wolff N, Byrd JC, et al. Physician extenders for cost-effective management of hypercholesterolemia. J Gen Intern Med. 1996;11:277-286. [pmid: 8725976].
Scheer JK, Loper D, Wagner L, et al. The effect of cholesterol screening on college students. J Am Coll Health. 1992;41:106-110. [pmid: 1430672].
Schinke SP, Singer B, Cole K, et al. Reducing cancer risk among Native American adolescents. Prev Med. 1996;25:146-155. [pmid: 8860279].
Schliephake H, Ruffert K, Schneller T. Prospective study of the quality of life of cancer patients after intraoral tumor surgery. J Oral Maxillofac Surg. 1996;54:664-670. [pmid: 8648469].
Schlierf G, Schuler G, Hambrecht R, et al. Treatment of coronary heart disease by diet and exercise. J Cardiovasc Pharmacol. 1995;25(suppl 4):S32-S34. [pmid: 8907212].
Schlundt DG, McDonel EC, Langford HG. Compliance in dietary management of hypertension. Compr Ther. 1985;11:59-66.
Schmid TL, Jeffery RW, Onstad L, et al. Demographic, knowledge, physiological, and behavioral variables as predictors of compliance with dietary treatment goals in hypertension. Addictive Behav. 1991;16(3-4):151-160.
Schoenthaler SJ. The effect of sugar on the treatment and control of antisocial behavior: A double-blind study of an incarcerated juvenile population. Int J Biosoc Res. 1982;3:1-9.
Schoenthaler SJ. Diet and delinquency: A multi-state replication. Int J Biosocial Res. 1983;5:70-78.
Schroeder JS, Gao SZ. Calcium blockers and atherosclerosis: Lessons from the Stanford Transplant Coronary Artery Disease/Diltiazem Trial. Can J Cardiol. 1995;11:710-715. [pmid: 7671182].
Schroeder JS, Gao SZ, Hunt SA, et al. Accelerated graft coronary artery disease: Diagnosis and prevention. J Heart Lung Transplantation. 1992;11(4 II suppl):S258-S266.
Schwartz GG, Oliver, MF, Ezekowitz MD, et al. Rationale and design of the myocardial ischemia reduction with aggressive cholesterol lowering (MIRACL) study that evaluates atorvastatin in unstable angina pectoris and in non-Q-wave acute myocardial infarction. Am J Cardiol. 1998;81:578-581. [pmid: 9514453].
Self M, Brewer A, Kumanyika S, et al. Pilot study to enhance start-up of a multicenter nutrition intervention trial. J Am Diet Assoc. 1998;98:322-325. [pmid: 9508016].
Shannon B, Greene G, Stallings V, et al. A dietary education program for hypercholesterolemic children and their parents. J Am Diet Assoc. 1991;91:208-212. [pmid: 1704025].
Shannon BM, Tershakovec AM, Martel JK, et al. Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94:923-927. [pmid: 7971012].
Shapiro H, Weinkove C, Coxon A, et al. Three year hospital experience with control of major obesity by VLCD in medically compromised individuals. Int J Obes. 1989;13 suppl 2:125-129. [pmid: 2613407].
Shike M. Diet and lifestyle in the prevention of colorectal cancer: An overview. Am J Med. 1999;106(1 A):11S-15S. [pmid: 10089108].
Shike M, Winawer SJ, Greenwald PH, et al. Primary prevention of colorectal cancer. Bull WHO. 1990;68:377-385. [pmid: 2203551].
Shisslak CM, Gray N, Crago M. Health care professionals' reactions to working with eating disorder patients. Int J Eating Disord. 1989;8:689-694.
Shreve ST, Kumanyika S. Geriatric assessment: Can primary care fill the void? [letter]. J Am Geriatr Soc. 1997;45:1407-1408. [pmid: 9361672].
Silagy C, Muir J, Coulter A, et al. Lifestyle advice in general practice: Rates recalled by patients. BMJ. 1992;305(6858).
Simkin-Silverman L, Wing RR, Hansen DH, et al. Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24:509-517. [pmid: 8524727].
Simmons D, Fleming C, Voyle J, et al. A pilot urban church-based programme to reduce risk factors for diabetes among Western Samoans in New Zealand. Diabetic Med. 1998;15:136-142. [pmid: 9507914].
Simon MS, Heilbrun LK, Boomer A, et al. A randomized trial of a low-fat dietary intervention in women at high risk for breast cancer. Nutr Cancer. 1997;27:136-142. [pmid: 9121940].
Simons LA, Andersen N, Simons J, et al. Health attitudes and knowledge, and coronary risk factors in high-school children, Sydney and Inverell. Med J Aust. 1982;2:178-183. [pmid: 6982392].
Simons-Morton BG, Baranowski T, Parcel GS, et al. Children's frequency of consumption of foods high in fat and sodium. Am J Prev Med. 1990;6:218-227. [pmid: 2223169].
Simons-Morton BG, Coates TJ, Saylor KE, et al. Great Sensations: A program to encourage heart healthy snacking by high school students. J School Health. 1984;54:288-291. [pmid: 6567715].
Simons-Morton BG, Parcel GS, Baranowski T, et al. Promoting physical activity and a healthful diet among children: Results of a school-based intervention study. Am J Public Health. 1991;81:986-991. [pmid: 1854016]. [pmcid: 1405714].
Singh RB, Niaz MA, Ghosh S. Effect on central obesity and associated disturbances of low-energy, fruit- and vegetable-enriched prudent diet in north Indians. Postgrad Med J. 1994;70(830).
Singleton JC, Achterberg CL, Shannon BM. Role of food and nutrition in the health perceptions of young children. J Am Diet Assoc. 1992;92:67-70. [pmid: 1728626].
Skrabal F, Aubock J, Hortnagl H. Low sodium/high potassium diet for prevention of hypertension: Probable mechanisms of action. Lancet. 1981;2(8252).
Sleight P. Lipid-lowering drugs: Potential for primary and secondary prevention. J Vascular Med Biol. 1994;5:125-128.
Smith KW, McKinlay SM, McKinlay JB. The reliability of health risk appraisals: A field trial of four instruments. Am J Public Health. 1989;79:1603-1607. [pmid: 2817186]. [pmcid: 1349761].
Smucker DR, Konrad TR, Curtis P, et al. Practitioner self-confidence and patient outcomes in acute low back pain. Arch Fam Med. 1998;7:223-228. [pmid: 9596455].
Snead DR, Vryenhoef P, Pinder SE, et al. Routine audit of breast fine needle aspiration (FNA) cytology specimens and aspirator inadequate rates. Cytopathology. 1997;8:236-247. [pmid: 9252741].
Soffer EE, Mitros F, Doornbos JF, et al. Morphology and pathology of radiation-induced esophagitis: Double-blind study of naproxen vs placebo for prevention of radiation injury. Dig Dis Sci. 1994;39:655-660. [pmid: 8131705].
Soltesz KS, Price JH, Johnson LW, et al. Family physicians' perceptions of barriers to patients' dietary change. Percept Motor Skills. 1994;78(3, Pt 1):968-970. [pmid: 8084720].
Sorensen G, Hunt MK, Morris DH, et al. Promoting healthy eating patterns in the worksite: The Treatwell intervention model. Health Educ Res. 1990;5:505-515.
Sorensen G, Morris DM, Hunt MK, et al. Work-site nutrition intervention and employees' dietary habits: The Treatwell program. Am J Public Health. 1992;82:877-880. [pmid: 1316722]. [pmcid: 1694162].
Sorensen G, Stoddard A, Macario E. Social support and readiness to make dietary changes. Health Educ Behav. 1998;25:586-598. [pmid: 9768379].
Sorensen G, Stoddard A, Ockene JK, et al. Worker participation in an integrated health promotion/health protection program: Results from the WellWorks project. Health Educ Q. 1996;23:191-203. [pmid: 8744872].
Sorensen G, Thompson B, Glanz K, et al. Work site-based cancer prevention: Primary results from the Working Well Trial. Am J Public Health. 1996;86:939-947. [pmid: 8669517].
Sorensen G, Thomson S, Hixson ML, et al. Measure of food choice behavior related to intervention messages. J Nutr Educ. 1997;29:3-11.
Sourander LB, Ruikka I, Kasanen A. A health survey on the aged with a 5-year follow-up. Acta Socio-Medica Scandinavica. 1970;3(suppl):1-41.
Sparks P, Shepherd R, Wieringa N, et al. Barriers to healthy eating: An examination of perceived behavioural control and unrealistic optimism. Appetite. 1994;23.
Sparks P, Shepherd R, Wieringa N, et al. Perceived behavioural control, unrealistic optimism and dietary change: An exploratory study. Appetite. 1995;24:243-255. [pmid: 7574571].
Srinath U, Jonnalagadda SS, Naglak MC, et al. Diet in the prevention and treatment of atherosclerosis: A perspective for the elderly. Clin Geriatr Med. 1995;11:591-611. [pmid: 8556689].
Stamler R, Stamler J, Grimm R, et al. Nonpharmacological control of hypertension. Prev Med. 1985;14:336-345. [pmid: 3903735].
Stampfer MJ, Hennekens CH, Manson JE, et al. Vitamin E consumption and the risk of coronary disease in women. N Engl J Med. 1993;328:1444-1449. [pmid: 8479463].
Stampfer MJ, Rimm EB. Epidemiologic evidence for vitamin E in prevention of cardiovascular disease. Am J Clin Nutr. 1995;62(6 suppl):1365S-1369S. [pmid: 7495232].
Steel JM, Young RJ, Lloyd GG, et al. Abnormal eating attitudes in young insulin-dependent diabetics. Br J Psychiatry. 1989;155:515-521. [pmid: 2611574].
Steinbrecher UP. Dietary antioxidants and cardioprotection-Fact or fallacy?. Can J Physiol Pharmacol. 1997;75:228-233. [pmid: 9164706].
Stern MP, Farquhar JW, Maccoby N, et al. Results of a 2-year health education campaign on dietary behavior: The Stanford Three Community Study. Circulation. 1976;54:826-833. [pmid: 975479].
Stern MP, Taylor CB. Response of dietary patterns to a two-year cardiovascular health education campaign: The Stanford Three-Community Study. In: Tillotson JL, ed. Proceedings of the Nutrition-Behavioral Research Conference. Bethesda, MD: National Institutes of Health. 1976:21-31. [pmcid: 169999].
Stewart L. Diet and behaviour. Aust N Z J Dev Disabil. 1989;15:157-158.
Stolley MR, Fitzgibbon ML. Effects of an obesity prevention program on the eating behavior of African American mothers and daughters. Health Educ Behav. 1997;24:152-164. [pmid: 9079575].
Stone EJ, Osganian SK, McKinlay SM, et al. Operational design and quality control in the CATCH multicenter trial. Prev Med. 1996;25:384-399. [pmid: 8818063].
Strom SS, Baldwin BJ, Sigurdson AJ, et al. Cosmetic saline breast implants: A survey of satisfaction, breast-feeding experience, cancer screening, and health. Plast Reconstr Surg. 1997;100(6).
Strychar IM, Champagne F, Ghadirian P, et al. Impact of receiving blood cholesterol test results on dietary change. Am J Prev Med. 1998;14:103-110. [pmid: 9631161].
Sueta CA, Carey TS, Burnett CK. Reassessment of indications for digoxin; Are patients being withdrawn?. Arch Intern Med. 1989;149:609-612. [pmid: 2919937].
Superko HR, Greenland P, Manchester RA, et al. Effectiveness of low-dose colestipol therapy in patients with moderate hypercholesterolemia. Am J Cardiol. 1992;70:135-140. [pmid: 1626496].
Sutherland HJ, Carlin K, Harper W, et al. A study of diet and breast cancer prevention in Canada: Why healthy women participate in controlled trials. Cancer Causes & Control. 1993;4:521-528. [pmid: 8280829].
Sutton S, Bickler G, Sancho-Aldridge J, et al. Prospective study of predictors of attendance for breast screening in inner London. J Epidemiol Community Health. 1994;48:65-73. [pmid: 8138773].
Swahn E, von Schenck H, Olsson AG. Omega-3 ethyl ester concentrate decreases total apolipoprotein CIII and increases antithrombin III in postmyocardial infarction patients. Clin Drug Invest. 1998;15:473-482.
Sylvester GP, Williams J, Achterberg C. Food and nutrition messages in film: A preliminary content analysis. Ann N Y Acad Sci. 1993;699:295-297. [pmid: 8267332].
Symonds RP. Treatment-induced mucositis: An old problem with new remedies. Br J Cancer. 1998;77:1689-1695. [pmid: 9635851].
Takamatsu S, Takamatsu M, Satoh K, et al. Effects on health of dietary supplementation with 100 mg d-alpha-tocopheryl acetate, daily for 6 years. J Int Med Res. 1995;23:342-357. [pmid: 8529777].
Tallberg T, Uusitalo R. Study of the effect of biological nutritional supplementation on the recurrency rate of ocular melanoma. Zeitschrift Fur Onkologie. 1997;29:1-6.
Tanaka T. Chemoprevention of human cancer: Biology and therapy. Crit Rev in Oncol-Hematol. 1997;25:139-174. [pmid: 9177939].
Tariciotti G, Iannetti A. Prevention and screening of colorectal cancer. Annali Italiani Di Medicina Interna. 1998;13:217-226. [pmid: 10349203].
Tayback M, Kumanyika S, Chee E. Body weight as a risk factor in the elderly. Arch of Intern Med. 1990;150:1065-1072. [pmid: 2331187].
Taylor PR, Li B, Dawsey SM, et al. Prevention of esophageal cancer: The nutrition intervention trials in Linxian, China. Cancer Research. 1994;54(7 suppl):2029s-2031s. [pmid: 8137333].
Taylor PR, Wang GQ, Dawsey SM, et al. Effect of nutrition intervention on intermediate endpoints in esophageal and gastric carcinogenesis. Am J Clin Nutr. 1995;62(6 suppl):1420S-1423S. [pmid: 7495241].
Tchekmedyian NS, Hickman M, Heber D. Treatment of anorexia and weight loss with megestrol acetate in patients with cancer or acquired immunodeficiency syndrome. Semin Oncol. 1991;18(1 suppl 2):35-42. [pmid: 1992535].
Teikari JM, Laatikainen L, Virtamo J, et al. Six-year supplementation with alpha-tocopherol and beta-carotene and age-related maculopathy. Acta Ophthalmologica Scandinavica. 1998;76:224-229. [pmid: 9591958].
Teikari JM, Virtamo J, Rautalahti M, et al. Long-term supplementation with alpha-tocopherol and beta-carotene and age-related cataract. Acta Ophthalmologica Scandinavica. 1997;75:634-640. [pmid: 9527321].
TenHave TR, Van Horn B, Kumanyika S, et al. Literacy assessment in a cardiovascular nutrition education setting. Patient Educ Counseling. 1997;31:139-150.
Terry P, Nyren O, Yuen J. Protective effect of fruits and vegetables on stomach cancer in a cohort of Swedish twins. Int J Cancer. 1998;76:35-37. [pmid: 9533759].
Tershakovec AM, Shannon BM, Achterberg CL, et al. One-year follow-up of nutrition education for hypercholesterolemic children. Am J Public Health. 1998;88:258-261. [pmid: 9491017]. [pmcid: 1508171].
Thaler BI, Paulin JM, Phelan EL, et al. A pilot study to test the feasibility of salt restriction in a community. N Z Med J. 1982;95(721).
Thigpen JT, Ehrlich CE, Creasman WT, et al. Phase II study of maytansine in the treatment of advanced or recurrent adenocarcinoma of the ovary: A Gynecologic Oncology Group study. Am J Clin Oncol. 1983;6:273-275. [pmid: 6846245].
Thompson B, Omenn G, Sexton M, et al. Worksite smoking cessation: A test of two programs. Prog Clin Biol Res. 1987;248:93-100. [pmid: 3671423].
Thompson IM, Coltman CA. Screening for prostate cancer: Opportunities for prevention. Sem Urol Oncol. 1996;1 (suppl 2):4-11.
Thorell B, Svardsudd K. Intervention against ischaemic heart disease risk factors in primary health care in a semi-rural community: The population study "50-year-old people in Kungsor.". Scand J Primary Health Care. 1994;12:51-56.
Tibblin G, Aberg H. Non-pharmacological treatment of hypertension: Differences between health centres in patients' blood pressure and success at withdrawal from drugs. Fam Prac. 1990;7:47-51.
Tilley BC, Glanz K, Kristal AR, et al. Nutrition intervention for high-risk auto workers: Results of the Next Step Trial. Prev Med. 1999;28:284-292. [pmid: 10072747].
Tilley BC, Vernon SW, Glanz K, et al. Worksite cancer screening and nutrition intervention for high-risk auto workers: Design and baseline findings of the Next Step Trial. Prev Med. 1997;26:227-235. [pmid: 9085392].
Tilley BC, Vernon SW, Myers R, et al. Planning the next step: A screening promotion and nutrition intervention trial in the work site. Ann N Y Acad Sci. 1995;768:296-299. [pmid: 8526371].
Tillotson JL, Bartsch GE, Gorder D, et al. Chapter 5. Food group and nutrient intakes at baseline in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65(1 suppl):228S-257S. [pmid: 8988940].
Tillotson JL, Gorder DD, DuChene AG, et al. Quality control in the Multiple Risk Factor Intervention Trial Nutrition Modality. Control Clin Trials. 1986;7(3 suppl):66S-690S. [pmid: 3802847].
Toma S, Losardo PL, Vincent M, et al. Effectiveness of beta-carotene in cancer chemoprevention. Eur J Cancer Prev. 1995;4:213-224. [pmid: 7647689].
Tonkin A, Alyward P, Colquhoun D, et al. Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels. N Engl J Med. 1998;339:1349-1357. [pmid: 9841303].
Toobert DJ, Glasgow RE, Nettekoven LA, et al. Behavioral and psychosocial effects of intensive lifestyle management for women with coronary heart disease. Patient Educ Counseling. 1998;35:177-188.
Toporoff E, Hebert JR. A proxy approach to the determination of total caloric intake for use in cancer epidemiology. Nutr Cancer. 1990;13(1-2):35-49. [pmid: 2300493].
Torgerson JS, Agren L, Sjostrom L. Effects on body weight of strict or liberal adherence to an initial period of VLCD treatment. A randomised, one-year clinical trial of obese subjects. Int J Obes Related Metab Disord. 1999;23:190-197.
Treatment of Mild Hypertension Research Group. The treatment of mild hypertension study. A randomized, placebo-controlled trial of a nutritional-hygienic regimen along with various drug monotherapies. The Treatment of Mild Hypertension Research Group. Arch Intern Med. 1991;151:1413-1423. [pmid: 2064494].
Trenkner LL, Achterberg CL. Use of focus groups in evaluating nutrition education materials. J Am Diet Assoc. 1991;91:1577-1581. [pmid: 1960352].
Trenkner LL, Rooney B, Viswanath K, et al. Development of a scale using nutrition attitudes for audience segmentation. Health Educ Res. 1990;5:479-487.
Tritchler D. Explanatory analyses of randomized studies. Biometrics. 1996;52:1450-1456. [pmid: 8962463].
Trudeau E, Kristal AR, Li S, et al. Demographic and psychosocial predictors of fruit and vegetable intakes differ: Implications for dietary interventions. J Am Diet Assoc. 1998;98:1412-1417. [pmid: 9850109].
Tsou KC, Lo KW, Schwarz R, et al. The oncofetal relationship of 5'-nucleotide phosphodiesterase-V isoenzyme. In: Fishman WH, Sell S, eds. Onco-Developmental Gene Expression. New York, NY: Academic Press. 1976:769-772. [pmcid: 170459].
Tsubono Y, Okubo S, Hayashi M, et al. A randomized controlled trial for chemoprevention of gastric cancer in high-risk Japanese population: Study design, feasibility and protocol modification. Jpn J Cancer Res. 1997;88:344-349. [pmid: 9197524].
Tsugane S, Tsubono Y, Okubo S, et al. A pilot study for a randomized controlled trial to prevent gastric cancer in high-risk Japanese population: Study design and feasibility evaluation. Japanese J Cancer Res. 1996;87:676-679.
Tudor-Smith C, Nutbeam D, Moore L, et al. Effects of the Heartbeat Wales programme over 5 years on behavioural risks for cardiovascular disease: Quasi-experimental comparison of results from Wales and a matched reference area. BMJ. 1998;316(7134):818-22. [pmcid: 28483]. [pmid: 9549451].
Tuomilehto J, Puska P, Tanskanen A, et al. A community-based intervention study on the feasibility and effects of the reduction of salt intake in North Karelia, Finland. Acta Cardiologica. 1981;36:83-104. [pmid: 6974941].
Turnin MC, Beddok RH, Clottes JP, et al. Telematic expert system Diabeto. New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15:204-212. [pmid: 1547677].
Tyroler HA. Nutrition and coronary heart disease epidemiology. Adv Exp Med Biol. 1995;369:7-19. [pmid: 7598018].
Urban N, White E, Anderson GL, et al. Correlates of maintenance of a low-fat diet among women in the Women's Health Trial. Prev Med. 1992;21:279-291. [pmid: 1614990].
Uusitupa MI. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann of Med. 1996;28:445-449. [pmid: 8949977].
Vaddadi KS. Gluten free/gluten load trial. Br J Psychiatry. 1986;149.
Valimaki MJ, Kinnunen K, Volin L, et al. A prospective study of bone loss and turnover after allogeneic bone marrow transplantation: Effect of calcium supplementation with or without calcitonin. Bone Marrow Transplantation. 1999;23:355-361. [pmid: 10100579].
Van Horn L, Donato K, Kumanyika S, et al. The dietitian's role in developing and implementing the first federal obesity guidelines. J Am Diet Assoc. 1998;98:1115-1117. [pmid: 9787716].
Verne J, Kettner J, Mant D, et al. Self-administered faecal occult blood tests do not increase compliance with screening for colorectal cancer: Results of a randomized controlled trial. Eur J Cancer Prev. 1993;2:301-305. [pmid: 8358281].
Vlissides DN, Venulet A, Jenner FA. A double-blind gluten-free/gluten-load controlled trial in a secure ward population. Br J Psychiatry. 1986;148:447-452. [pmid: 3524724].
Vogel LA, Showe LC, Lester TL, et al. Direct binding of IL-12 to human and murine B lymphocytes. Int Immunol. 1996;8:1955-1962. [pmid: 8982780].
Wahlqvist ML, Wattanapenpaiboon N, Macrae FA, et al. Changes in serum carotenoids in subjects with colorectal adenomas after 24 mo of beta-carotene supplementation. Am J Clin Nutr. 1994;60:936-943. [pmid: 7985637].
Wallin E, Bremberg S, Haglund B, et al. Cancer prevention in schools: Design and pilot testing of a nutritional curriculum for mid-adolescents. J Cancer Educ. 1993;8:145-150. [pmid: 8395867].
Walter HJ, Hofman A, Connelly PA, et al. Coronary heart disease prevention in childhood: One-year results of a randomized intervention study. Am J Prev Med. 1986;2:239-245. [pmid: 3453186].
Walter HJ, Hofman A, Vaughan RD, et al. Modification of risk factors for coronary heart disease: Five-year results of a school-based intervention trial. N Engl J Med. 1988;318:1093-1100. [pmid: 3281016].
Waltzer KB. Simple, sensible preventive measures for managed care settings. Geriatrics. 1998;53(10):65-68, 75-77, 81-82. [pmid: 9791197].
Wara WM, Jenkin RD, Evans A, et al. Tumors of the pineal and suprasellar region: Children's cancer study group treatment results 1960-1975 -- A report from Children's Cancer Study Group. Cancer. 1979;43:698-701. [pmid: 105801].
Warden N, Duncan M, Sommars E. Nutritional changes heighten children's achievement: A 5-year study. Int J Biosoc Res. 1982;3:72-74.
Wardle J, Solomons W. Naughty but nice: A laboratory study of health information and food preferences in a community sample. Health Psychol. 1994;13:180-183. [pmid: 8020461].
Watanabe H, Kakihana M, Ohtsuka S, et al. Randomized, double-blind, placebo-controlled study of supplemental vitamin E on attenuation of the development of nitrate tolerance. Circulation. 1997;96:2545-2550. [pmid: 9355892].
Watanabe H, Kakihana M, Ohtsuka S, et al. Randomized, double-blind, placebo-controlled study of the preventive effect of supplemental oral vitamin C on attenuation of development of nitrate tolerance. J Am Coll Cardiol. 1998;31:1323-1329. [pmid: 9581727].
Webber LS, Frank GC, Smoak CG. Cardiovascular risk factors from birth to 7 years of age: The Bogalusa Heart Study -- Design and participation. Pediatrics. 1987;80(5 Pt 2):767-778. [pmid: 3670987].
Weidner G. Correlates of health behavior change: The family heart study. Homeostasis in Health & Dis. 1994;35:235-242.
Welty FK. Vitamin remedies, natural supplements in the prevention of heart disease in women. Infertility Reprod Med Clin North Am. 1999;10:259-275.
Whelton PK, Appel LJ, Espeland MA, et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: A randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279:839-846. [pmid: 9515998].
Whelton PK, Kumanyika SK, Cook NR, et al. Efficacy of nonpharmacologic interventions in adults with high-normal blood pressure: Results from phase 1 of the Trials of Hypertension Prevention. Trials of Hypertension Prevention Collaborative Research Group. Am J Clin Nutr. 1997;65(2 suppl):652S-660S. [pmid: 9022561].
White E, Shattuck AL, Kristal AR, et al. Maintenance of a low-fat diet: Follow-up of the Women's Health Trial. Cancer Epidemiol Biomarkers Prev. 1992;1:315-323. [pmid: 1338896].
Wiesemann A, Metz J, Nuessel E, et al. Four years of practice-based and exercise-supported behavioural medicine in one community of the German CINDI area: Countrywide Integrated Non-Communicable Diseases Intervention. Int J Sports Med. 1997;18:308-315. [pmid: 9231850].
Willett W. Nutritional Epidemiology. 2nd ed. New York, NY: Oxford University Press; 1998.
Willett WC, Sampson L, Stampfer MJ, et al. Reproducibility and validity of a semi-quantitative food frequency questionnaire. Am J Epidemiol. 1985;122:51-65. [pmid: 4014201].
Williams CL, Squillace MM, Bollella MC, et al. Healthy Start: A comprehensive health education program for preschool children. Prev Med. 1998;27:216-223. [pmid: 9578999].
Williams JD, Achterberg C, Sylvester GP. Target marketing of food products to ethnic minority youth. Ann N Y Acad Sci. 1993;699:107-114. [pmid: 8267301].
Wilson CM, Rimer BK, Bennett DJ, et al. Educating the older cancer patient: Obstacles and opportunities. Health Educ Q. 1984;10:76-87. [pmid: 6706619].
Wilt VM, Gums JG. 'Isolated' low high-density lipoprotein cholesterol. Ann Pharmacother. 1997;31:89-97. [pmid: 8997473].
Winett RA, Moore JF, Wagner JL, et al. Altering shoppers' supermarket purchases to fit nutritional guidelines: An interactive information system. J Appl Behav Analysis. 1991;24:95-105.
Winett RA, Wagner JL, Moore JF, et al. An experimental evaluation of a prototype public access nutrition information system for supermarkets. Health Psychol. 1991;10:75-78. [pmid: 2026133].
Winkler G, Doring A, Keil U, et al. Comparison of dietary intakes in four selected European populations. Clin Investigator. 1992;70:889-895.
Winterfeldt EA. A.D.A. urges Congress to make nutritional care a reimbursable benefit in Medicare's home health care. Am Diet Assoc J. 1979;75:460, 467-468.
Wood DA. Aetiology of ischaemic heart disease. Br J Anaesth. 1988;61:3-10. [pmid: 3044417].
Woodside JV, Yarnell JW, McMaster D, et al. Effect of B-group vitamins and antioxidant vitamins on hyperhomocysteinemia: A double-blind, randomized, factorial-design, controlled trial. Am J Clin Nutr. 1998;67:858-866. [pmid: 9583842].
World Cancer Research Fund and American Institute for Cancer Research. Food, Nutrition and the Prevention of Cancer: A Global Perspective. Washington, DC: World Cancer Research Fund, 1997.
Wright J, Wood B, Hale G. Evaluation of group versus individual nutrition education in overweight patients with myocardial infarction. Aust N Z J Med. 1981;11:497-501. [pmid: 6948541].
Wyshak G, Lamb GA, Lawrence RS, et al. A profile of the health-promoting behaviors of physicians and lawyers. N Engl J Med. 1980;303:104-107. [pmid: 7383061].
Xu X, Duncan AM, Merz BE, et al. Effects of soy isoflavones on estrogen and phytoestrogen metabolism in premenopausal women. Cancer Epidemiol, Biomarkers Prev. 1998;7:1101-1108. [pmid: 9865428].
Yellowitz J, Horowitz AM, Goodman HS, et al. Knowledge, opinions and practices of general dentists regarding oral cancer: A pilot survey. J Am Dent Assoc. 1998;129:579-583. [pmid: 9601170].
Yoshida S, Kaibara A, Yamasaki K, et al. Effect of glutamine supplementation on protein metabolism and glutathione in tumor-bearing rats. JPEN: J Parenter Enteral Nutr. 1995;19:492-497. [pmid: 8748364].
Zafari AM, Wenger NK. Secondary prevention of coronary heart disease. Arch Phys Med Rehabil. 1998;79:1006-1017. [pmid: 9710178].
Zatonski W, Kwiatkowska J, Baranowski T, et al. Investigations on the activity of glycolytic erythrocytic enzymes in polycythemia vera. Polish Med J. 1971;10:819-822. [pmid: 4256716].
Zeltzer PM, Marangos PJ, Sather H, et al. Prognostic importance of serum neuron specific enolase in local and widespread neuroblastoma. Prog in Clin Biol Res. 1985;175:319-329. [pmid: 3991735].
Zhou JR, Blackburn GL. Bridging animal and human studies: What are the missing segments in dietary fat and prostate cancer?. Am J Clin Nutr. 1997;66(6 suppl):1572S-1580S. [pmid: 9394717].
Ziegler RG, Mayne ST, Swanson CA. Nutrition and lung cancer. Cancer Causes & Control. 1996;7:157-177. [pmid: 8850443].