# References

1 Doll R, Peto R. The causes of cancer: Quantitative estimates of avoidable risks of cancer in the United States today. J Natl Cancer. 1981;66:1191-1308. [pmid: 7017215].
2 Miller AB, Berrino F, Hill M, et al. Diet in the aetiology of cancer: A review. Eur J Cancer. 1994;30:207-220.
3 American Cancer Society 1996 Advisory Committee on Diet, Nutrition, and Cancer Prevention. Guidelines on diet, nutrition, and cancer prevention: Reducing the risk of cancer with healthy food choices and physical activity. CA-A Cancer J for Clinicians. 1996;25:325-341.
4 National Cholesterol Education Program Adult Treatment Panel II. Summary of the second report of the National Cholesterol Education Program (NCEP) expert panel on detection, evaluation, and treatment of high blood cholesterol in adults (adult treatment panel II). JAMA. 1993;269:3015-3023. [pmid: 8501844].
5 Glanz K. Behavioral research contributions and needs in cancer prevention and control: Dietary change. Prev Med. 1997;26:S43-S55. [pmid: 9327492].
6 Willet W. Nutritional Epidemiology. 2nd ed. New York, NY: Oxford University Press, 1998.
7 Food, Nutrition and the Prevention of Cancer: A Global Perspective. Washington, DC: World Cancer Research Fund, 1997.
8 Roth MJ, Guo-Qing W, Lewin KJ, et al. Histopathologic changes seen in esophagectomy specimens from the high-risk region of Linxian, China: Potential clues to an etiologic exposure?. Hum Pathol. 1998;29(11):1294-8. [pmid: 9824110].
9 Omenn GS, Goodman GE, Thornquist MD, et al. Risk factors for lung cancer and for intervention effects in CARET, the beta-carotene and retinol efficacy trial. J Natl Cancer Inst. 1996;88:1550-1559. [pmid: 8901853].
10 Huttunen JK. Health effects of supplemental use of antioxidant vitamins: Experiences from the alpha-tocopherol beta-carotene (ATBC) cancer prevention study. Scandinavian Journal of Nutrition/Naringsforskning. 1995;39:103-104.
11 Christen WG, Gaziano JM, Hennekens CH. Design of Physicians' Health Study II: A randomized trial of beta-carotene, vitamins E and C, and multivitamins, in prevention of cancer, cardiovascular disease, and eye disease, and review of results of completed trials. Ann Epidemiol. 2000;10:125-134. [pmid: 10691066].
12 Alberts DS, Martinez ME, Roe DJ, et al. Lack of effect of a high-fiber cereal supplement on the recurrence of colorectal adenomas. N Engl J Med. 2000;342:1156-1162. [pmid: 10770980].
13 Schatzkin A, Lanza E, Corle D, et al. Lack of effect of a low-fat, high-fiber diet on the recurrence of colorectal adenomas. N Engl J Med. 2000;342:1149-1155. [pmid: 10770979].
14 Denke MA. Cholesterol-lowering diets: A review of the evidence. Arch Intern Med. 1995;155:17-26. [pmid: 7802517].
15 Hersey JC, Burnbauer L, Bellamy H, et al. Progress and Accomplishments of the Statewide Nutrition Education Network Cooperative Agreement Program: Year One. Report to the Food and Consumer Service, USDA (Contract No. FCS-53-3198-5-038). Research Triangle Park, NC: Research Triangle Institute and Health Systems Research, 1997.
16 Rimer BK. Mammography use in the US: Trends and the impact of interventions. Ann Behav Med. 1995;16:317-326.
17 Glanz K, Lewis FM, Rimer BK (eds). Health Behavior and Health Education: Theory, Research, and Practice. San Francisco, CA: Jossey-Bass, 1997.
18 Green LW, Kreuter MW, Deeds SG, et al. Health Education Planning: A Diagnostic Approach. Palo Alto, CA: Mayfield, 1980.
19 Walter HJ, Hofman A, Vaughan RD, et al. Modification of risk factors for coronary heart disease: Five-year results of a school-based intervention trial. N Engl J Med. 1988;318:1093-1100. [pmid: 3281016].
20 Parcel GS, Simons-Morton B, O'Hara NM, et al. School promotion of healthful diet and physical activity: Impact on learning outcomes and self-reported behavior. Health Educ Q. 1989;16:181-199. [pmid: 2732062].
21 Simons-Morton BG, Parcel GS, Baranowski T, et al. Promoting physical activity and a healthful diet among children: Results of a school-based intervention study. Am J Public Health. 1991;81:986-991. [pmid: 1854016]. [pmcid: 1405714].
22 Resnicow K, Cohn L, Reinhardt J, et al. A 3-year evaluation of the Know Your Body Program in inner-city schoolchildren. Health Educ Q. 1992;19:463-480. [pmid: 1452447].
23 Domel SB, Baranowski T, Davis H, et al. Development and evaluation of a school intervention to increase fruit and vegetable consumption among 4th and 5th grade students. J Nutr Educ. 1993;25:345-349.
24 Luepker RV, Perry CL, McKinlay SM, et al. Outcomes of a field trial to improve children's dietary patterns and physical activity: The Child and Adolescent Trial for Cardiovascular Health (CATCH) collaborative group. JAMA. 1996;275:768-776. [pmid: 8598593].
25 Lytle LA, Stone EJ, Nichaman MZ, et al. Changes in nutrient intakes of elementary school children following a school-based intervention: Results from the CATCH Study. Prev Med. 1996;25:465-477. [pmid: 8818069].
26 Osganian SK, Ebzery MK, Montgomery DH, et al. Changes in the nutrient content of school lunches: Results from the CATCH Eat Smart Food service intervention. Prev Med. 1996;25:400-412. [pmid: 8818064].
27 Perry CL, Lytle LA, Feldman H, et al. Effects of the Child and Adolescent Trial for Cardiovascular Health (CATCH) on fruit and vegetable intake. J Nutr Educ. 1998;30:354-360. [pmid: 9532074].
28 Nader PR, Stone EJ, Lytle LA, et al. Three-year maintenance of improved diet and physical activity: The CATCH cohort -- Child and Adolescent Trial for Cardiovascular Health. Arch Pediatr Adolesc Med. 1999;153:695-704. [pmid: 10401802].
29 Baxter AP, Milner PC, Hawkins S, et al. The impact of heart health promotion on coronary heart disease lifestyle risk factors in schoolchildren: Lessons learnt from a community-based project. Public Health. 1997;111:231-237. [pmid: 9242036].
30 Harrell JS, Gansky SA, McMurray RG, et al. School-based interventions improve heart health in children with multiple cardiovascular disease risk factors. Pediatrics. 1998;102(2 Pt 1):371-380. [pmid: 9685441].
31 Resnicow K, Davis M, Smith M, et al. Results of the TeachWell worksite wellness program. Am J Public Health. 1998;88:250-257. [pmid: 9491016].
32 Nicklas TA, Johnson CC, Myers L, et al. Outcomes of a high school program to increase fruit and vegetable consumption: Gimme 5 -- a fresh nutrition concept for students. J School Health. 1998;68:248-253. [pmid: 9719999].
33 Perry CL, Bishop DB, Taylor G, et al. Changing fruit and vegetable consumption among children: The 5-a-Day Power Plus program in St. Paul, Minnesota. Am J Public Health. 1998;88:603-609. [pmid: 9551002]. [pmcid: 1508423].
34 Baranowski T, Davis M, Resnicow K, et al. Gimme 5 fruit, juice, and vegetables for fun and health: Outcome evaluation. Health Educ Behav. 2000;27:96-111. [pmid: 10709795].
35 Reynolds KD, Franklin FA, Binkley D, et al. Increasing the fruit and vegetable consumption of 4th-graders: Results from the High 5 Project. Prev Med. 2000;30(4):309-319. [pmid: 10731460].
36 Hjermann I, Velve Byre K, Holme I, et al. Effect of diet and smoking intervention on the incidence of coronary heart disease: Report from the Oslo Study Group of a randomised trial in healthy men. Lancet. 1981;2(8259):1303-1310. [pmid: 6118715].
37 Gorder DD, Doleck TA, Coleman GG, et al. Dietary intake in the multiple risk factor intervention trial (MRFIT): Nutrient and food group changes over 6 years. J Am Diet Assoc. 1986;86:744-751. [pmid: 3519736].
38 Lee-Han H, Cousins M, Beaton M, et al. Compliance in a randomized clinical trial of dietary fat reduction in patients with breast dysplasia. Am J Clin Nutr. 1988;48:575-586. [pmid: 3046298].
39 Burr ML, Fehily AM, Gilbert JF, et al. Effects of changes in fat, fish, and fibre intakes on death and myocardial reinfarction: Diet and reinfarction trial (DART). Lancet. 1989;2:757-761. [pmid: 2571009].
40 Glasgow RE, Toobert DJ, Mitchell DL, et al. Nutrition education and social learning interventions for type II diabetes. Diabetes Care. 1989;12:150-152. [pmid: 2702897].
41 Baron JA, Gleason R, Crowe B, et al. Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Prac. 1990;40(333):137-141.
42 Bloomfield S, Calder JE, Chisholm V, et al. A project in diabetes education for children. Diabetic Med. 1990;7:137-142. [pmid: 2137754].
43 Campbell LV, Barth R, Gosper JK, et al. Impact of intensive educational approach to dietary change in NIDDM. Diabetes Care. 1990;13:841-847. [pmid: 2209318].
44 Insull W Jr, Henderson MM, Prentice RL, et al. Results of a randomized feasibility study of a low-fat diet. Arch Intern Med. 1990;150:421-427. [pmid: 2405805].
45 Nordevang E, Ikkala E, Callmer E, et al. Dietary intervention in breast cancer patients: Effects on dietary habits and nutrient intake. Eur J Clin Nutr. 1990;44:681-687. [pmid: 2261900].
46 Holm LE, Nordevang E, Ikkala E, et al. Dietary intervention as adjuvant therapy in breast cancer patients: A feasibility study. Breast Cancer Res Treatment. 1990;16:103-109.
47 Nordevang E, Callmer E, Marmur A, et al. Dietary intervention in breast cancer patients: Effects on food choice. Eur J Clin Nutr. 1992;46:387-396. [pmid: 1639046].
48 Ornish D, Brown SE, Scherwitz LW, et al. Can lifestyle changes reverse coronary heart disease? The Lifestyle Heart Trial. Lancet. 1990;336(8708):129-133. [pmid: 1973470].
49 Hanefeld M, Fischer S, Schmechel H, et al. Diabetes intervention study: Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14:308-317. [pmid: 2060433].
50 Nikolaus T, Schlierf G, Vogel G, et al. Treatment of coronary heart disease with diet and exercise: Problems of compliance. Ann Nutr Metab. 1991;35:1-7.
51 Beresford SAA, Farmer EMZ, Feingold L, et al. Evaluation of a self-help dietary intervention in a primary care setting. Am J Public Health. 1992;82:79-84. [pmid: 1311152].
52 Glasgow RE, Toobert DJ, Hampson SE, et al. Improving self-care among older patients with type II diabetes: The "Sixty Something..." Study. Patient Educ Counseling. 1992;19:61-74.
53 Kristal AR, White E, Shattuck AL, et al. Long-term maintenance of a low-fat diet: Durability of fat-related dietary habits in the Women's Health Trial. J Am Diet Assoc. 1992;92:553-559. [pmid: 1573135].
54 White E, Shattuck AL, Kristal AR, et al. Maintenance of a low-fat diet: Follow-up of the Women's Health Trial. Cancer Epidemiol Biomarkers Prev. 1992;1:315-323. [pmid: 1338896].
55 Chlebowski RT, Blackburn GL, Buzzard IM, et al. Adherence to a dietary fat intake reduction program in postmenopausal women receiving therapy for early breast cancer: The Women's Intervention Nutrition Study. J Clin Oncol. 1993;11:2072-2080. [pmid: 8229121].
56 Haber D, Lacy MG. Evaluation of a socio-behavioral intervention for changing health behaviors of older adults. Behav Health Aging. 1993;3:73-85.
57 Laitinen JH, Ahola IE, Sarkkinen ES, et al. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93:276-283. [pmid: 8382712].
58 Cupples ME, McKnight A. Randomised controlled trial of health promotion in general practice for patients at high cardiovascular risk. BMJ. 1994;309(6960):993-996. [pmid: 7950723].
59 DeBusk RF, Miller NH, Superko HR, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Arch Intern Med. 1994;120:721-729.
60 Heller RF, Walker RJ, Boyle CA, et al. A randomised controlled trial of a dietary advice program for relatives of heart attack victims. Med J Aust. 1994;161:529-531. [pmid: 7968751].
61 McKeown-Eyssen GE, Bright-See E, Bruce WR, et al. A randomized trial of a low fat high fibre diet in the recurrence of colorectal polyps. J Clin Epidemiol. 1994;47:525-536. [pmid: 7730878].
62 Rankinen T, Rauramaa R, Vaisanen S, et al. Blood coagulation and fibrinolytic factors are unchanged by aerobic exercise or fat modified diet. Randomized clinical trial in middle-aged men. Fibrinolysis. 1994;8:48-53.
63 Shannon BM, Tershakovec AM, Martel JK, et al. Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94:923-927. [pmid: 7971012].
64 Tershakovec AM, Shannon BM, Achterberg CL, et al. One-year follow-up of nutrition education for hypercholesterolemic children. Am J Public Health. 1998;88:258-261. [pmid: 9491017]. [pmcid: 1508171].
65 Lindholm LH, Ekbom T, Dash C, et al. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310(6987):1105-1109. [pmid: 7742677].
66 Renaud S, de Lorgeril M, Delaye J, et al. Cretan Mediterranean diet for prevention of coronary heart disease. Am J Clin Nutr. 1995;61(6 suppl):1360S-1367S. [pmid: 7754988].
67 De Lorgeril M, Renaud S, Mamelle N, et al. Mediterranean alpha-linolenic acid-rich diet in secondary prevention of coronary heart disease. Lancet. 1994;343(8911):1454-1459. [pmid: 7911176].
68 De Lorgeril M, Salen P, Martin JL, et al. Mediterranean dietary pattern in a randomized trial: Prolonged survival and possible reduced cancer rate. Arch Intern Med. 1998;158:1181-1187. [pmid: 9625397].
69 De Lorgeril M, Salen P, Martin JL, et al. Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: Final report of the Lyon Diet Heart Study. Circulation. 1999;99:779-785. [pmid: 9989963].
70 Simkin-Silverman L, Wing RR, Hansen DH, et al. Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24:509-517. [pmid: 8524727].
71 Aish A. A comparison of female and male cardiac patients' response to nursing care promoting nutritional self-care. Can J Cardiovasc Nurs. 1996;7:4-13. [pmid: 9136305].
72 Boyd NF, Martin LJ, Beaton M, et al. Long-term effects of participation in a randomized trial of a low-fat, high-carbohydrate diet. Cancer Epidemiol, Biomarkers Prev. 1996;5:217-222. [pmid: 8833622].
73 Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. 1996;19:835-842. [pmid: 8842601].
74 Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Counseling. 1997;32:175-184.
75 Grimm RH Jr, Flack JM, Grandits GA, et al. Long-term effects on plasma lipids of diet and drugs to treat hypertension. Treatment of Mild Hypertension Study (TOMHS) Research Group. JAMA. 1996;275:1549-1556. [pmid: 8622245].
76 Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-1511. [pmid: 9314625].
77 Bakx JC, Stafleu A, van Staveren WA, et al. Long-term effect of nutritional counseling: A study in family medicine. Am J Clin Nutr. 1997;65(6 suppl):1946S-1950S. [pmid: 9174500].
78 Beresford SAA, Curry SJ, Kristal AR, et al. A dietary intervention in primary care practice: The eating patterns study. Am J Public Health. 1997;87:610-616. [pmid: 9146440].
79 Boyd NF, Lockwood GA, Greenberg CV, et al. Effects of a low-fat high-carbohydrate diet on plasma sex hormones in premenopausal women: Results from a randomized controlled trial. Br J Cancer. 1997;76:127-135. [pmid: 9218745].
80 Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism: Clin Exp. 1997;46(12 suppl 1):50-55.
81 Kristal AR, Shattuck AL, Bowen DJ, et al. Feasibility of using volunteer research staff to deliver and evaluate a low-fat dietary intervention: The American Cancer Society Breast Cancer Dietary Intervention Project. Cancer Epidemiol, Biomarkers Prev. 1997;6:459-467. [pmid: 9184781].
82 Roderick P, Ruddock V, Hunt P, et al. A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47:7-12. [pmid: 9115804].
83 Simon MS, Heilbrun LK, Boomer A, et al. A randomized trial of a low-fat dietary intervention in women at high risk for breast cancer. Nutr Cancer. 1997;27:136-142. [pmid: 9121940].
84 Aubin M, Godin G, Vezina L, et al. Hypercholesterolemia screening: Does knowledge of blood cholesterol level affect dietary fat intake?. Can Fam Physician. 1998;44:1289-1297. [pmid: 9640523].
85 Campbell NC, Ritchie LD, Thain J, et al. Secondary prevention in coronary heart disease: A randomised trial of nurse led clinics in primary care. Heart. 1998;80:447-452. [pmid: 9930042].
86 Ornish D. Avoiding revascularization with lifestyle changes: The Multicenter Lifestyle Demonstration Project. Am J Cardiol. 1998;82(10B):72T-76T. [pmid: 9671012].
87 Coates RJ, Bowen DJ, Kristal AR, et al. The Women's Health Trial Feasibility Study in Minority Populations: Changes in dietary intakes. Am J Epidemiol. 1999;149:1104-1112. [pmid: 10369504].
88 Bauer RL, Heller RF, Challah S. United Kingdom Heart Disease Prevention Project: 12-year follow-up of risk factors. Am J Epidemiol. 1985;121:563-569. [pmid: 4014145].
89 Sorensen G, Morris DM, Hunt MK, et al. Work-site nutrition intervention and employees' dietary habits: The Treatwell program. Am J Public Health. 1992;82:877-880. [pmid: 1316722]. [pmcid: 1694162].
90 Hanlon P, McEwen J, Carey L, et al. Health checks and coronary risk: Further evidence from a randomised controlled trial. BMJ. 1995;311(7020):1609-1613. [pmid: 8555805].
91 Sorensen G, Thompson B, Glanz K, et al. Work site-based cancer prevention: primary results from the Working Well Trial. Am J Public Health. 1996;86:939-947. [pmid: 8669517].
92 Reynolds KD, Gillum JL, Hyman DJ, et al. Comparing two strategies to modify dietary behavior and serum cholesterol. J Cardiovasc Risk. 1997;4:1-5. [pmid: 9215513].
93 Strychar IM, Champagne F, Ghadirian P, et al. Impact of receiving blood cholesterol test results on dietary change. Am J Prev Med. 1998;14:103-110. [pmid: 9631161].
94 Anderson J, Dusenbury L. Worksite cholesterol and nutrition: An intervention project in Colorado. AAOHN J. 1999;47:99-106. [pmid: 10347395].
95 Buller DB, Morrill C, Taren D, et al. Randomized trial testing the effect of peer education at increasing fruit and vegetable intake. J Natl Cancer Inst. 1999;91:1491-1500. [pmid: 10469751].
96 Tilley BC, Glanz K, Kristal AR, et al. Nutrition intervention for high-risk auto workers: Results of the Next Step Trial. Prev Med. 1999;28:284-292. [pmid: 10072747].
97 Kristal AR, Glanz K, Tilley BC, et al. Mediating factors in dietary change: Understanding the impact of a worksite nutrition intervention. Health Educ Behav. 2000;27:112-125. [pmid: 10709796].
98 Stern MP, Farquhar JW, McCoby N, et al. Results of a 2-year health education campaign on dietary behavior: The Stanford Three Community Study. Circulation. 1976;54:826-833. [pmid: 975479].
99 Jaycox S, Baranowski T, Nader PR, et al. Theory-based health education activities for third to sixth grade children. J School Health. 1983;53:584-588. [pmid: 6558280].
100 Nader PR, Baranowski T, Vanderpool NA, et al. The family health project: Cardiovascular risk reduction education for children and parents. J Dev Behav Pediatr. 1983;4:3-10. [pmid: 6833501].
101 Nader PR, Sallis JF, Patterson TL, et al. A family approach to cardiovascular risk reduction: Results from the San Diego Family Health Project. Health Educ Q. 1989;16:229-244. [pmid: 2732065].
102 Baranowski T, Henske J, Simons-Morton B, et al. Dietary change for cardiovascular disease prevention among Black-American families. Health Educ Res. 1990;5:433-433.
103 Knutsen SF, Knutsen R. The Tromso Survey: The Family Intervention Study -- the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20:197-212. [pmid: 2057468].
104 Turnin MC, Beddok RH, Clottes JP, et al. Telematic expert system Diabeto: New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15:204-212. [pmid: 1547677].
105 Rodgers AB, Kessler LG, Portnoy B, et al. "Eat for Health": A supermarket intervention for nutrition and cancer risk reduction. Am J Public Health. 1994;84:72-76. [pmid: 8279615].
106 Cox RH, Parker GG, Watson AC, et al. Dietary cancer risk of low-income women and change with intervention. J Am Diet Assoc. 1995;95:1031-1034. [pmid: 7657907].
107 Fitzgibbon ML, Stolley MR, Avellone ME, et al. Involving parents in cancer risk reduction: A program for Hispanic American families. Health Psychol. 1996;15:413-422. [pmid: 8973920].
108 Brug J, Steenhuis I, van Assema P, et al. The impact of a computer-tailored nutrition intervention. Prev Med. 1996;25:236-242. [pmid: 8781000].
109 Cullen KW, Bartholomew LL, Parcel GS. Girl Scouting: An effective channel for nutrition education. J Nutr Educ. 1997;29:86-91.
110 Hartman TJ, McCarthy PR, Park RJ, et al. Results of a community-based low-literacy nutrition education program. J Community Health. 1997;22:325-341. [pmid: 9353681].
111 Pierce JP, Faerber S, Wright FA, et al. Feasibility of a randomized trial of a high-vegetable diet to prevent breast cancer recurrence. Nutr Cancer. 1997;28:282-288. [pmid: 9343838].
112 Stolley MR, Fitzgibbon ML. Effects of an obesity prevention program on the eating behavior of African American mothers and daughters. Health Educ Behav. 1997;24:152-164. [pmid: 9079575].
113 Havas S, Anliker J, Damron D, et al. Final results of the Maryland WIC 5-A-Day Promotion Program. Am J Public Health. 1998;88:1161-1167. [pmid: 9702141]. [pmcid: 1508288].
114 Marcus AC, Morra M, Rimer BK, et al. A feasibility test of a brief educational intervention to increase fruit and vegetable consumption among callers to the Cancer Information Service. Prev Med. 1998;27:250-261. [pmid: 9579004].
115 Marcus AC, Heimendinger J, Wolfe P, et al. Increasing fruit and vegetable consumption among callers to the CIS: Results from a randomized trial. Prev Med. 1998;27(5 Pt 2):S16-S28. [pmid: 9808821].
116 Simmons D, Fleming C, Voyle J, et al. A pilot urban church-based programme to reduce risk factors for diabetes among Western Samoans in New Zealand. Diabetic Med. 1998;15:136-142. [pmid: 9507914].
117 Tudor-Smith C, Nutbeam D, Moore L, et al. Effects of the Heartbeat Wales programme over 5 years on behavioural risks for cardiovascular disease: Quasi-experimental comparison of results from Wales and a matched reference area. BMJ. 1998;316(7134):818-822. [pmcid: 28483]. [pmid: 9549451].
118 Brug J, Glanz K, van Assema P, et al. The impact of computer-tailored feedback and iterative feedback on fat, fruit, and vegetable intake. Health Educ Behav. 1998;25:517-531. [pmid: 9690108].
119 Campbell MK, Demark-Wahnefried W, Symons M, et al. Fruit and vegetable consumption and prevention of cancer: The Black Churches United for Better Health project. Am J Public Health. 1999;89:1390-1396. [pmid: 10474558]. [pmcid: 1508774].
120 Lutz SF, Ammerman AS, Atwood JR, et al. Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99:705-709. [pmid: 10361533].
121 Brug J, Steenhuis I, van Assema P, et al. Computer-tailored nutrition education: differences between two interventions. Health Educ Res. 1999;14:249-256. [pmid: 10387504].
122 Campbell MK, Honess-Morreale L, Farrell D, et al. A tailored multimedia nutrition education pilot program for low-income women receiving food assistance. Health Educ Res. 1999;14:257-267. [pmid: 10387505].
123 Di Buono M, Hanna JS, Katzel LI, et al. Weight loss due to energy restriction suppresses cholesterol biosynthesis in overweight, mildly hypercholesterolemic men. J Nutr. 1999;129:1545-1548. [pmid: 10419988].
124 Buescher PA, Larson LC, Nelson MD, et al. Prenatal WIC participation can reduce low birth weight and newborn medical costs: A cost-benefit analysis of WIC participation in North Carolina. J Am Diet Assoc. 1993;93:163-166. [pmid: 8423280].
125 Franz MJ, Splett PL, Monk A, et al. Cost-effectiveness of medical nutrition therapy provided by dietitians for persons with non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1995;95:1018-1024. [pmid: 7657903].
126 Orleans CT. Promoting the maintenance of health behavior change: Recommendations for the next generation of research and practice. Health Psychol. 2000;19:76-83. [pmid: 10709951].
127 Glanz K. Progress in dietary behavior change. Am J Health Promot. 1999;14:112-117. [pmid: 10724722].
128 Kumanyika SK, Bowen D, Rolls BJ, et al. Maintenance of dietary behavior change. Health Psychol. 2000;19:42-56. [pmid: 10709947].
129 McKinlay JB. The new public health approach to improving physical activity and autonomy in older populations. In: Heikkinen E, ed., Preparation for Aging. New York, NY: Plenum Press; 1995:87-103.
130 McKinlay JB. A case for re-focusing upstream: The political economy of illness. In: Enelow AJ, Henderson JB, eds., Applying Behavioral Science to Cardiovascular Risk. Seattle, WA: American Heart Association. 1975:7-18. [pmcid: 186900].
131 Kumanyika SK, Obarzanek E, Stevens V, et al. Weight loss experience of black and white participants in NHLBI-sponsored clinical trials. Am J Clin Nutr. 1991;53 (6 suppl):1631S-1638S. [pmid: 2031498].
132 Kahn HS, Williamson DF, Stevens JA. Race and weight change in US women: the roles of socioeconomic and marital status. Am J Public Health. 1991;81:319-323. [pmid: 2036117].