# Future Research

Two important objectives of this evidence-based review are (1) to assess the state of the science in the area of behavioral dietary interventions to reduce cancer risk and (2) to make recommendations regarding directions for future research. In this chapter, we address two main topics related to this objective. First, we identify intervention approaches and target populations that appear to be understudied. Second, we offer recommendations about study design and measurement strategies that will facilitate future evidence-based reviews. We suggest guidelines for the description of methods and results in manuscripts that we believe will improve the reporting of research findings and enhance our ability to synthesize the literature.

## Interventions and Population Subgroups Requiring Additional Study

Using our key questions as a guide, much more research is available to answer Key Question 1 (evidence that one type of intervention or combination of interventions is more effective than another) than to address either Key Question 2 (evidence for efficacy of dietary interventions by subgroup, particularly related to ethnicity and gender) or Key Question 3 (cost-effectiveness of interventions).

### Intervention Setting

We began the literature review process using a slight modification of the Rimer typology of behavioral interventions, which has been described by Rimer and others as a guide to the categories of interventions we anticipated finding.^16-18^ This typology classifies interventions into eight categories: individual-directed (including school, community, worksite, and health care settings), system- and physician-directed interventions, access-enhancing interventions, policy-level interventions, media campaigns (including broadcast and print media, and point-of-purchase interventions) community-based interventions multistrategy interventions, and tailored interventions or interventions using emerging technologies.

Recognizing overlap among a number of categories, the vast majority of the studies in this evidence report looked at individual-directed interventions, including those in the three subsections of school, community, and health care settings. Although we identified studies in most of the categories listed, our inclusion criteria specifying pre- and postintervention measures of individual dietary intake meant that many of these studies were not eligible. For example, we found several supermarket point-of-purchase intervention studies. Generally, the outcomes for these studies included such things as changes in food purchasing behaviors, changes in knowledge or awareness, and sometimes shelf disappearance data. We also found a few studies reporting on media campaigns and policy-level interventions, such as the 5-A-Day program in California, but, again, measures did not include individual level of dietary change.

Thus, more research is needed that uses dietary intervention categories within the Rimer typology but also includes assessment of dietary change at the individual level. Including this level of measurement will facilitate comparisons across widely different intervention approaches.

A series of papers presented at a recent meeting, "Maintenance of Behavior Change in Cardiorespiratory Risk Reduction" (sponsored by the National Heart, Lung, and Blood Institute [NHLBI]) and published in Health Psychology, offers recommendations for new models of population health-behavior change and maintenance that integrate individual-level with broader environmental- and societal-level policy influences.^126-128^ Using McKinlay's Population-Based Health Promotion Model,^129-130^ they describe dietary interventions as downstream (individual-level interventions for those at risk), midstream (population-level prevention strategies targeting defined groups), and upstream (macro-level state and national public policy and environmental interventions). Our review clearly suggests that, to date, the majority of work has been done in the "downstream" category. As researchers move "upstream," they will face new challenges in designing innovative interventions and evaluations to promote change and measure the impact in a way that will help identify highly effective strategies.

An area of considerable interest to the National Cancer Institute is emerging technologies in health communications. These technologies often include sophisticated computer tailoring systems providing participant feedback and education based on individual assessment data. Innovative uses of lower-level technologies (such as telephone and mail) are also being tested. Several studies published in this area include data on individual dietary change, but no "critical mass" of this literature exists yet that would allow comparisons with other intervention approaches.

These gaps suggest that one important area of future research will be to assess the degree to which new health communication technologies, either alone or in combination with more traditional intervention approaches, can improve diet-related behavior-change outcomes. Also important will be the evaluation of Internet-based intervention approaches that reach beyond the standard one-on-one and group counseling approaches to both increase efficiency and reach a broader audience, particularly those who are not reached by traditional intervention approaches.

### Cost-Effectiveness

As described earlier, we found very scant information about Key Question 3 concerning what conclusions (if any) can be reached about the cost-effectiveness of these types of interventions. Cost-effectiveness data should be collected as a part of intervention evaluation research whenever possible. This will be particularly important as part of evaluating emerging technological approaches (e.g., Web-based interventions), which may require a very large "front end" investment but then potentially allow for reaching a broad audience using fewer personnel resources. Investigators should not confuse cost-benefit analyses, which are far more complex and often arbitrary, with a more focused cost-effectiveness approach. Although research teams can collect cost-related data retrospectively, planning the necessary data collection instruments and procedures from the initiation of their projects will greatly facilitate their inclusion and the accurate conduct of economic analyses.

### Intervention Intensity, Follow-Up, and Maintenance

Unfortunately, we were unable to determine whether greater intervention intensity was associated with more significant changes in dietary outcome measures. Given the limited detail often included in intervention descriptions, assessment of intensity level was a rough estimate at best, and we did not have sufficient numbers of studies that were clearly of "high" or "low" intensity. Nonetheless, critical to the development of cost-effective interventions is the ability to determine the optimal "dose" or duration needed to effect significant change at reasonable cost. This question could be addressed more directly with research efforts that compare several levels of intervention intensity within the same study.

Our review also reveals that few studies follow participants for more than a year from the beginning of the intervention and that few include a clearly defined maintenance intervention designed to prevent relapse over time. At the same time, there is strong epidemiologic evidence for the association between long-term dietary practices and chronic disease outcomes. Thus, a critical area for research is the development and evaluation of innovative approaches to cost-effective, long-term intervention strategies that facilitate maintenance of positive dietary change. Intervention trials ought to include an adequate length of follow-up to determine whether intervention effects are sustained after the formal intervention period has ended. Presenters at the NHLBI conference described above called for more theory-based and interdisciplinary research on the maintenance process and for interventions that address more than one behavioral risk at a time.^126^

### Understudied Population Subgroups

Much more additional research is needed to answer more effectively Key Question 2: What is the evidence by subgroup (focus on ethnicity) and for males and females within these groups? We reviewed numerous studies that included only men or only women. However, the studies were vastly different in terms of intervention design and outcomes measurement, so comparison was not possible. A limited number of studies that include men and women in the same intervention reported effect sizes by gender. Perhaps of greatest interest is not whether men are more successful than women (or vice versa) in changing their diets, but rather which intervention components or mediating variables are most important for each sex. For example, is support group attendance associated with greater positive changes in one sex or the other? Do women achieve better dietary change when they have a concomitant increase in self-efficacy? Do men with higher levels of perceived health threat show greater changes in diet? If we can gain a greater understanding of some of these associations, we will be better able to design interventions tailored to the needs of the audience.

Thanks, in part, to funding priorities of federal and local agencies, more studies in recent years have included and/or emphasized underserved and minority subgroups. However, much additional work is needed in this area. As mentioned previously in this report, few studies either targeted or included subgroup analysis for low-income or minority populations. Given that these groups are generally at highest risk for cancer and other chronic diseases,^131-132^ the need for intervention research is great.

This research should not simply test the same interventions that have been applied in nonminority, middle- to upper-income populations; rather, it should represent innovative strategies to reach traditionally hard-to-reach groups. Intervention studies including adequate numbers of ethnic subgroups should include subgroup analysis to determine effectiveness across groups.

As with research specific to male-female differences in intervention acceptability and impact described above, such studies will need to collect good process and mediator data in order to understand the impact of specific components of the intervention as well as the intervening variables that are necessary to effect dietary change.

Too little is known about why people eat what they do. More research specific to the cause of specific dietary behaviors will ultimately help us improve the design and evaluation of interventions. Pilot studies should be designed to detect changes in mediating variables, initial field studies to assess individual-level dietary change, and second-level field studies to detect changes in subgroups.

## Recommendations About Study Design, Measurement, and Reporting

Any researchers who have embarked on the daunting task of an evidence-based review quickly become aware of the inconsistencies and deficiencies in the currently published literature. Our recommendations here closely parallel any general advice to researchers about study design and measurement. Investigators should be aware that failure to meet many of these criteria will mean that their research may be excluded from evidence-based reviews. In other cases, our recommendations are aimed at improving the ability of future evidence reviewers to answer important emerging questions about the efficacy of behavioral dietary interventions.

### Study Design

Attention to a number of basic study design and measurement issues would greatly improve the available literature in the field of behavioral dietary change that serves as the basis for evidence reviews. A certain amount of flexibility in these areas is important to facilitate inclusion of a broader variety of intervention strategies, but most of these recommendations should be achievable with nearly any intervention approach.

All intervention evaluation studies should include a control or at least a comparison group. When possible, group assignment should be random, and both baseline and follow-up data should be collected for both groups. A legitimate concern among intervention researchers is the need to keep control group participants adequately invested in the study so that they are willing to complete follow-up data collection. For individual-level studies, this can be accomplished by close communication with participants and incentives to stay involved. For community-level intervention research, a delayed intervention approach, or "interim" nondiet interventions during the study period, are often helpful in maintaining involvement of the control group. Because we were interested in the issue of intensity of intervention experience by control groups, we conducted a set of analyses looking at whether the differences in change in dietary behavior were larger with studies that used either strict "usual care" or a very minimal intervention for the control group. Our results did not support an association between intervention success and intensity of the control group (data not shown).

### Measures

Ideally, all dietary assessment measures and lengths of follow-up should be standardized to facilitate comparisons across studies. Practically, studies addressing dietary interventions to reduce cancer risk should measure fruit and vegetable intake based on total servings per day and assess dietary fat intake based on grams of total fat and saturated fat; they should also evaluate both types of intake as a percentage of total calories. Recognizing the need for cultural adaptation of dietary assessment instruments and the biases inherent in self-report measures, it is critical that investigators ensure the validity of their instruments and methods relative to the study population. Other dietary measures that may facilitate the intervention or provide more behaviorally oriented data (such as food preparation practices) are encouraged, but they should be accompanied by more standardized measures to facilitate broader comparisons. The timing of follow-up measures is largely dependent on the intervention length and design. We strongly encourage that one data collection point follow immediately after the intervention period. For cross-study comparison purposes, standardized follow-up periods such as 3 months, 6 months, 1 year, and 2 years should be encouraged.

### Reporting

Even a very well-designed and -conducted study will be excluded from an evidence review if a few basic data reporting guidelines are not followed. At a minimum, all manuscripts should include the statistics needed for meta-analysis. This includes the mean and standard error or standard deviation for all outcome measures as well as actual p values (not just significance cut-points) for both significant and nonsignificant findings. Journal editors could facilitate this process by setting similar criteria for review. Other seemingly basic information that is often omitted from manuscripts includes complete information about sample size and loss to follow-up at each measurement period.

Finally, for the efficacy of an intervention to be evaluated, it must be adequately described. Intervention researchers face the challenge of condensing the description of very complex and multifaceted programs into the tight page limitations of most journals. One solution is to describe the intervention more comprehensively in a baseline or methods paper, but publishing this kind of paper can be difficult. Based on our sense of the literature and on the requirements for a rigorous evidence review process, the intervention elements that we believe are critical to include are information needed to assess generalizability (e.g., the recruitment pool), response rates for individuals and sites (e.g., schools, worksites), the elements of intervention intensity (number of contacts or exposures, delivery channels, length of active intervention period, environmental exposures or manipulations), title and training of individuals involved with intervention delivery, the specific behavioral theories used and how they are applied to the intervention, and the existence and extent of ongoing reinforcement or maintenance interventions.

## Summary

An evidence review provides an excellent opportunity to clarify the existing data on a particular topic and to identify areas of need for future research. Recognizing the increased role of rigorous evidence-based reviews in synthesizing the literature on any particular topic, we believe that researchers engaged in this process should also offer recommendations for research methodology and reporting that can facilitate and enhance future such reviews. Behavioral dietary interventions for cancer risk reduction are highly diverse in terms of intervention approach, study design, data collection, analysis, and reporting. Randomized controlled trials evaluating theory-based interventions are relatively new to this literature. The availability of biologic markers that can be used to validate self-reported dietary change, particularly in the area of cancer, is likely to increase rapidly in the next several years. Therefore, we anticipate that future evidence-based reviews and updates in the area of behavioral dietary change will continue to offer significant insight into this rapidly developing area of research.