# Conclusions

## Fruits and Vegetables

Approximately one-third of the studies we reviewed reported results of behavioral dietary interventions on fruit and vegetable intake. Based on the small number of studies reporting such information and the high degree of variability across these studies, we concluded that a formal meta-analysis was inappropriate. Therefore, we employed the remaining two analysis strategies in our determination of the impact of interventions on fruit and vegetable intake. The results of both the differences-in-deltas approach and the summary of significant findings approach indicated that (a) dietary interventions were positively associated with changes in fruit and vegetable intake and (b) when these outcomes are measured individually, changes in fruit intake are more notable. While the range of studies reporting significant findings for fruit and vegetable intake varied (depending on the particular outcome measured), the vast majority of the studies we reviewed reported significant increases in fruit and vegetable intake (either as separate outcomes or combined). More than three-fourths of the studies in our review reported significant increases in fruit and vegetable intake (as a combined variable). Using the differences-in-deltas approach, we determined that the average increase in fruit and vegetable intake reported in the studies we reviewed was 0.6 servings per day.

While we were unable to explore the relative effectiveness of interventions on many population subgroups (because of the minimum cell size requirement we established for specific analyses to be conducted), our analyses suggested that interventions were more successful at increasing fruit intake among children and vegetable intake among adults. In addition, interventions conducted among higher disease risk populations were consistently more likely to report significant increases in fruit and vegetable intake.

Among the specific intervention characteristics we explored, several patterns were evident. Studies employing a theoretical basis were more likely to report significant increases in intake of fruits and vegetables than were studies that did not use theory. In addition, we observed a linear relationship between study quality (using procedures described in Chapter 2) and the likelihood of reporting significant findings. Also, the use of social support components in the interventions we reviewed was associated with greater increases in fruit and vegetable intake (using both analysis strategies). Finally, while studies that used goal setting and interactive activities involving food were more likely to report significant increases in fruit and vegetable intake, the magnitude of the increases was not notably higher than that in studies not employing such techniques. We did not have a large enough pool of articles to explore characteristics such as intervention intensity, setting, mode of delivery, or use of individually tailored or culturally/ethnically specific interventions.

## Dietary Fat

Nearly 90 percent of the articles we reviewed reported results for dietary fat, although there was a tremendous amount of variability in these outcomes. In determining the impact of behavioral dietary interventions on decreases in fat intake, we used all three analysis strategies. Based on all three techniques, dietary interventions were positively associated with changes in fat consumption. We observed similar decreases in intake of total fat and saturated fat (the two most commonly reported fat outcomes in the studies we reviewed). Among a subset of articles employing biochemical indicators (i.e., measuring changes in blood cholesterol), the decrease in total fat intake was significantly correlated with concomitant decreases in total blood cholesterol (r = 0.76). The change in saturated fat was not corroborated by decreases in total blood cholesterol.

The large number of studies reporting results for dietary fat enabled us to explore two moderating population characteristics: age and risk status. Although studies conducted among high-risk populations were not consistently more likely to report significant decrease in fat intake (across the five sets of fat outcomes we explored using the summary of significant findings approach), the differences-in-deltas analysis indicated that the magnitude of the change in dietary fat was notably higher among interventions conducted with higher-risk populations, particularly the reduction in saturated fat. The pattern of greater effects being observed among the studies focusing on high disease risk populations was also evident in our meta-analysis. In addition, interventions conducted among children appeared to be more successful at reducing intake of total fat and less successful at reducing intake of saturated fat than were interventions conducted among adults; however, only a very small number of studies measured fat intake among children.

Unlike the pattern observed for fruit and vegetable outcomes, interventions employing a theoretical framework were not consistently more likely to report significant effects (and the magnitude of the intervention effect was actually lower among studies using theory). Nor was study quality associated with the likelihood of reporting significant effects or the magnitude of the intervention effect. Among the specific intervention characteristics we explored, however, several consistent patterns were evident. The use of social support, small groups, and goal setting appeared particularly effective at reducing intake of dietary fat. Greater proportions of studies employing such strategies reported significant findings, and the magnitude of the change in dietary fat (using the differences-in-deltas approach) was notably higher among these studies. Although studies that involved families in the interventions and that used interactive food-related activities were more likely to report significant decreases in fat intake, the magnitude of the decrease was not higher than in studies that did not incorporate these special features. Finally, although very few studies were designed to be culturally or ethnically specific (to the study sample), our results suggest that such studies report greater decreases in dietary fat (although we did not have a sufficient number of articles to explore the magnitude of this decrease).

## Key Questions Addressed in the Report

In this evidence report, we posed three key questions about the efficacy of behavioral dietary interventions in reducing cancer risk. The background and the overall analytic framework for this work, with attention to specific concerns of the National Cancer Institute, were presented in Chapters 1 and 2. The specific questions were the following:

- Question 1 -- Is there evidence that one type of intervention or combination of interventions, using a broad typology of behavior interventions and including emerging technologies and approaches, is more effective than another for helping individuals or groups modify their diet to consume more fruits and vegetables and less fat?
- Question 2 -- What is the evidence by subgroup (e.g., African American, Hispanic, Asian American, Native American) and for males and females within these groups?
- Question 3 -- What conclusions (if any) can be reached about the cost-effectiveness of these types of interventions?

Because of the similarity of dietary recommendations for prevention of the major chronic diseases, we chose to include in our review articles addressing primary and, to a lesser extent, secondary prevention of cancer; coronary heart (cardiovascular) disease; and non-insulin-dependent (type 2) diabetes mellitus. Also included were studies using dietary intake as the final outcome, with no stated disease outcome. We excluded studies that tested therapeutic diets for specific health conditions, such as hypertension, type 1 diabetes, or obesity.

### Question 1: Comparative Effectiveness of Interventions

Our evidence review lends support to the notion that a wide variety of dietary interventions delivered in many different settings to individuals of different ages, ethnicities, and genders can have a positive impact on dietary behaviors associated with cancer risk reduction. The large proportion of studies showing favorable outcomes in various situations suggests an overall positive effect, although the potential for publication bias may have influenced the likelihood of identifying positive effects of interventions. The restriction of the literature search to papers published in English also provides a potential source of bias.

The lack of similarity across studies in outcome measures, study design, analysis strategy, and intervention technique makes it impossible to draw broad conclusions about the most efficacious behavioral dietary interventions. Nevertheless, our findings offer insight into intervention components that may hold promise for future research efforts. At the same time, our work did not necessarily support the efficacy of some commonly accepted intervention techniques and underpinnings. As we describe below, we urge caution in overinterpreting these findings until substantial additional research is conducted (see Chapter 5).

### Question 2: Effectiveness of Interventions by Subgroups

The number of studies available to address the second key question -- regarding evidence for the efficacy of dietary interventions by subgroup -- was very limited. This was particularly true for lower-income and minority subgroups among whom the burden of suffering due to cancer and other life-threatening or chronic diseases is greatest. More information was available to determine relative intervention effectiveness between other subgroups such as high-risk versus general-risk intervention participants and adults versus children.

### Question 3: Cost-Effectiveness of Interventions

Even fewer studies address the cost-effectiveness of dietary interventions. Some investigations that did include cost estimates did not meet our inclusion criteria for study design and measures. Among those studies meeting our criteria for inclusion, cost data were rare, and reporting of cost relative to the effectiveness of the intervention was almost nonexistent.

## Our Analytic Approach -- Advantages, Disadvantages, and Interpretation

As described in Chapters 2 and 3, we used multiple analytic strategies (including meta-analysis, differences-in-deltas, and analysis of the significance of the intervention effect) in an attempt to clarify the existing knowledge base and offer directions for future research. The diversity of study populations, interventions, study designs, and approaches to data analysis necessitated groupings and comparisons that varied according to the analytic strategy being employed.

Our most rigorous approach, meta-analysis, could be applied to the studies assessing change in dietary fat but not to change in fruit and vegetable intake, for which the number of studies was much smaller. The differences-in-deltas approach, which is based on a percentage magnitude of change, allowed us to accommodate a wider variety of outcome measures reported for fruits and vegetables as well as dietary fat, and thus to include a larger number of studies. The final approach, analysis of the significance of the intervention effect, although statistically the weakest, was also the most inclusive, allowing us to examine the broadest diversity of outcomes and approaches to statistical reporting.

Incorporating as many studies as possible in our efforts to synthesize and understand the dietary change literature is desirable, but the drawbacks to more inclusive analytic strategies must be recognized. The more inclusive the method, the closer one comes to the proverbial situation of comparing apples and oranges. Sometimes this problem arises from incomplete reporting of study methods or results. Other times, however, study outcomes may be strikingly different-for example, the percentage of calories from saturated fat versus the frequency with which skin is removed from chicken before consumption. Both outcomes indeed capture similar changes in dietary behavior, but the vast difference in their units and measurement approaches can make for unstable comparisons.

Casting ever-wider nets (through our three analysis strategies) also means that the results may not be comparable with each other. For example, we found that the differences-in-deltas approach suggested larger effect sizes in fruit and vegetable intake among interventions employing food-related activities, but the analysis of the significance of intervention effects approach suggested the reverse. The first method included 12 studies. By contrast, the second method comprised 22 studies, along with a much wider variety of "acceptable" outcome measures. When comparing other intervention characteristics, such as cultural/ethnic specificity, social support, or inclusion of a family component, the numbers of studies in each cell often become quite small, causing instability in the estimates. The establishment of a minimum number of studies as a prerequisite for conducting any of the secondary analysis strategies we employed, while preventing the generation of extremely unstable estimates, also prevented the exploration of several theoretically significant population and intervention characteristics (such as intervention intensity and setting).

## Broad Impact of Behavioral Dietary Interventions to Reduce Cancer Risk

### Meta-Analysis Results

Our highest level of confidence is in the meta-analytic approach. Unfortunately, as discussed in Chapter 3, we were unable to conduct a statistical meta-analysis or pooling for the fruit and vegetable intake outcomes because of the small number of studies and the unacceptable diversity of outcomes.

We were able to make some comparisons of the effectiveness of dietary behavioral interventions on total dietary fat intake across study settings, populations, and lengths of follow-up. Of the 80 studies reporting results for relevant (e.g., fat-related) outcomes, 28 were ultimately included in this meta-analysis. Although this approach did not provide a single overall estimate of the efficacy of behavioral interventions on dietary change, the results of the meta-analysis indicate the potential of these interventions for producing reductions in fat intake across a variety of different settings and study populations.

### Other Analyses

The differences-in-deltas approach allowed us to calculate median difference in percentage change in dietary outcomes of interest between intervention and control groups for selected outcome measures for all eligible articles (17/39 for fruits and vegetables, 34/80 for dietary fat). The median difference in percentage change in fruit and vegetable intake was +16.6 favoring the intervention group. This translates into a mean change in fruit and vegetable consumption among intervention groups of approximately 0.6 servings. For total fat as a percentage of energy intake, the median difference was a -15.7 percent change (i.e., a better result for the intervention groups). The estimate of mean change in total fat intake is a 7.3 percent reduction in the percentage of calories from fat. Most clinicians would consider this a moderate but clinically significant improvement in diet.

Results from the second and third analytic approaches used to compare different populations, settings, and intervention characteristics are best viewed in combination to assess overall trends. The problem with individualized comparisons is the wide variety of studies and the appreciable difference in the numbers of studies in many of the cells. Conclusions about these results (along with meta-analytic findings) are discussed under each key clinical question below.

## Conclusions Based on Key Questions

### Question 1: Comparative Effectiveness of Interventions

Several dietary intervention components appear to be promising in modifying dietary change. These factors include social support, goal setting, small groups, food-related activities, and the incorporation of family components. Interventions that included "interactions with food," such as cooking or taste testing, seemed particularly promising in increasing fruit and vegetable intake and reducing fat intake. As an example, based on our meta-analysis, one study with a nutritionist-delivered intervention in type 2 diabetes patients that also included social support, a family component, and goal setting reported a mean difference in change of 6.0 percent. ^76^ By contrast, another nutritionist-led intervention study augmented only with goal setting achieved a 3.0 percent mean difference in change. ^57^ While these findings are not surprising, they do support efforts by nutritionists and other health professionals to continue refining and evaluating the most effective intervention components with an eye toward achieving greater efficiency, less participant burden, and increased cost-effectiveness.

Another intervention component that appeared to have promise for dietary change (specifically, fat intake) was cultural or ethnic specificity. The number of studies that either included individual tailoring or specifically mentioned culturally sensitive interventions was so small that the estimates must be considered very unstable. In some cases, studies testing tailored interventions have compared different tailoring approaches without a usual-care control group. ^121^ Thus, the overall impact of tailoring on dietary change cannot be determined.

We had speculated that nutrition intervention studies that also included other lifestyle modification emphases might detract from the diet-related focus. Our review neither supported nor refuted this proposition. The meta-analysis for dietary fat did suggest that in one study among men the addition of a physical activity intervention seemed to bolster the dietary change outcomes. More research is needed to determine whether multiple lifestyle intervention strategies have a synergistic or a distracting effect on dietary change.

In our initial analyses with the non-meta-analytic techniques, we found limited support for a positive association between the use of a theoretical base for intervention design and positive dietary outcomes. From reviewing the literature, however, as well as recognizing that changes are occurring in federal specifications for "Requests for [Research] Applications" and in the evaluation criteria that grant review panels apply, we are aware that the use of behavior theory for intervention design has received much more emphasis in the past 5 years than previously. Therefore, we re-analyzed the data including only studies from 1995 onward. With this step, we found a suggestion of substantial positive association between theory application and positive dietary change. We had hoped to be able to classify the degree to which interventions were "theory driven" versus "theory informed," but few articles provided adequate detail to make this distinction.

We had hoped to determine whether interventions that include a maintenance component are more successful in helping participants sustain positive changes made as part of the initial intervention. Unfortunately, very few studies reported anything that could be clearly distinguished as maintenance. Even when articles reported longer-term follow-up, they usually did not provide information sufficient to determine if the intervention either included continued intervention elements or involved a specific approach designed to prevent relapse or maintain existing positive change. Not surprisingly, our meta-analytic results for dietary fat did suggest that continuing reinforcement of interventions may be associated with the maintenance of changes in behavior. However, few studies address the question of how long and at what intensity a maintenance intervention must be sustained to prevent relapse in the long run.

Dietary intervention studies involving health outcomes in which specific biological markers are associated with elevated risk (such as cholesterol for coronary heart disease) often include such outcome measures to corroborate assessment of dietary change. As we report in Chapter 3, positive findings with respect to self-reported dietary change scores accompanied by small or no difference with respect to measured changes in biological markers, such as blood lipids, are not uncommon in clinical trials of dietary interventions. This discrepancy may be attributable in part to social desirability bias on the part of participants -- that is, they know how they should be eating, and they are inclined to answer dietary assessment questions in a way that reflects this knowledge. Participants in the intervention groups of these studies may well make more appropriate dietary changes than do usual-care participants, but these changes were not fully reflected by the observed reductions in total and low-density lipoprotein (LDL) cholesterol.

### Question 2: Effectiveness of Interventions by Subgroups

Not surprisingly, interventions among higher-risk individuals or those already diagnosed with cancer, diabetes, or cardiovascular disease (CVD) seemed to have a greater impact than among those of general-risk status. These findings held true across all three levels of analysis. Some of the larger effects were associated with individuals who had already sustained a cardiovascular event and who participated in a very intensive and comprehensive lifestyle modification program.^48^ This fact may mean that such studies have only limited generalizability to the public at large. Indeed, subject willingness to participate in extremely intensive interventions may be closely tied to risk status. The potential confounding between subject motivation (and participation) and the intensity of intervention should be kept in mind when interpreting these results.

Interestingly, individuals diagnosed with type 2 diabetes showed much smaller effects than those with either cancer or CVD. We speculate that relative to individuals who have been diagnosed with cancer or who have had a cardiovascular event, diabetes may be perceived more as a chronic condition than as a life-threatening illness, and this factor may in turn be associated with the lower efficacy of interventions in this population. However, we offer this interpretation with considerable caution because the interventions for diabetic patients were not as intense as those for individuals with cancer or CVD. Moreover, heavy reliance on diabetes medications (oral agents and insulin) may distract both patient and provider from adequate attention to dietary change.

A limited number of studies reported results separately for males and females. As described above for the meta-analysis, we grouped some studies on the basis of the gender of participants, but these groupings did not allow direct comparisons of similar interventions by gender. Thus, we cannot explain through these methods the extent to which difference in the efficacy of the interventions may be attributable to gender.

Of particular interest in our review was the effort to assess the degree to which dietary interventions are effective in populations distinguished by ethnicity or income. Minority and low-income populations are at increased risk for many cancers as well as other chronic diseases associated with a high intake of fat and low consumption of fruits and vegetables. Of the 92 studies reported in our Evidence Tables, only a fraction either focused on a low-income population exclusively or made mention of including low-income individuals. Few of the latter studies conducted subanalyses to determine relative intervention effectiveness among different income groups. As reported for the meta-analyses of dietary fat, changes in the range of 6 percentage points were achieved in two community-based studies with low-income women (one with African Americans and one with Hispanics) who participated in a series of weekly education sessions over 12 weeks.^107^,^112^ Successful dietary changes in a handful of other studies either including or limited to low-income individuals add support to the notion that these interventions can be effective across socioeconomic strata. However, we cannot say anything definitive about relative levels of success or about what type of interventions are most effective among individuals for whom conventional interventions may be a poor fit with their needs.

Many of the studies we reviewed included an ethnically diverse population, but few included an adequate number of minorities for comparison purposes, and even fewer reported any analysis of effect size by minority subgroup. As with the income variable, we are not able to comment on relative levels of success of different interventions or types of intervention among specific minority groups. We can say, however, that our review supports the conclusion that many different kinds of interventions have shown at least modest success for ethnically diverse participants.

Our analysis of intervention components or characteristics did suggest potentially greater effectiveness among those studies reporting efforts to design culturally sensitive interventions. However, it was difficult to determine the extent of cultural sensitivity. Quite possibly, interventions could be culturally sensitive without being described as such, while interventions that are described as "culturally sensitive" may include only token efforts to be so. The limited level of intervention description in most manuscripts (attributable largely to page limitations by journals) makes it impossible to conduct a thorough assessment of the degree to which any intervention is "culturally sensitive."

### Question 3: Cost-Effectiveness of Interventions

Of the three key questions, our ability to answer the third was the most limited. Of those studies qualifying for inclusion in our Evidence Tables, none made more than a passing mention of cost associated with the intervention. Although some studies have assessed the cost or cost-effectiveness of dietary interventions,^124-125^ they have generally focused on aspects of nutrition and health beyond the scope of this review or have not included the study design and analysis required for inclusion in our body of evidence.

### Possible Harm

None of the dietary intervention studies we reviewed specifically evaluated the question of whether the intervention could or did result in harm to participants. Such an outcome is relatively unlikely with the types of dietary modifications implemented, but case studies have appeared in the literature regarding failure to thrive among infants and children whose parents were overly strident in restricting dietary fat. With any dietary intervention in adolescent girls, taking precautions against the possibility of eating disorders is prudent.

More recently, another potential harm related to interventions designed to reduce dietary fat intake has become apparent. Rising obesity levels in the face of declines in self-reported fat intake have raised the possibility that reduction in fat as a percentage of total intake has been accompanied by an increase in overall caloric intake. Presumably this is because people are eating larger quantities of low-fat foods, which are often quite high in simple carbohydrate sources of calories.