# Introduction

## Background and Significance

It has been estimated that one-third of all cancer mortality in the United States is related to diet.^1^,^2^ Based on a convergence of evidence indicating that nutrition plays an important role in the initiation, promotion, and progression of cancer, the National Cancer Institute (NCI) has recommended that Americans decrease fat consumption to 30 percent or less of total calories, increase fiber intake to 20 to 30 grams per day, and increase fruit and vegetable intake to five servings a day (the "5-A-Day" message). The American Cancer Society recommends choosing most foods from plant sources, limiting the intake of high-fat foods -- particularly from animal sources -- and limiting the consumption of alcohol.^3^ Similar guidelines have been disseminated for prevention of other diseases, such as cardiovascular disease (CVD).^4^

In the past decade, behavioral research on dietary change for cancer risk reduction has become more prevalent and rigorous. NCI has funded behavior change research at the level of $8.1 million annually,^5^ with a primary focus on diet. The National Heart, Lung, and Blood Institute (NHLBI) and the National Institute of Digestive Diseases, Diabetes, and Kidney Disease (NIDDK) have also spent millions on dietary intervention studies extending back at least 20 years. Many different intervention channels are being tested in a variety of populations. More recent studies employ theory-based interventions and measure intervening cognitive and psychological variables. In short, significant research is being done on dietary intervention efficacy, and at considerable expense.

Despite these two decades of dietary intervention research, no clear understanding has emerged regarding which interventions are most efficacious or effective in influencing dietary change, and for whom. (Hereafter, effectiveness should be understood to include efficacy in assessments of behavioral interventions.) Of particular concern are minority and underserved populations who appear to be at greatest risk for many cancers and other chronic diseases, yet are often most difficult to reach with screening and prevention programs. These gaps in understanding are the chief motivations for this evidence report.

Dietary behavior change is inextricably linked to social, environmental, cultural, and individual psychosocial and cognitive factors. Unlike in pharmacotherapy, a "single agent" approach to dietary change is neither feasible nor theoretically sound. The challenges are to develop innovative approaches to address the variety of barriers and motivators to change and then to test rigorously the impact of these interventions on dietary intake, biological markers, or both. This multifaceted approach creates many difficulties in evaluating the relative effectiveness of different intervention strategies, which tend not to be directly comparable in terms of objectives, methods, intensity or dose, or outcomes.

Thus, careful thought is needed to refine the research questions of interest, to define the parameters of the literature search and the review criteria, and to carry out a careful synthesis of the literature. These factors all argue for the production of an authoritative systematic review that will clarify the existing knowledge base, point the direction for future research, and lay the groundwork for others to determine which behavioral interventions to adopt, which to revise and adapt, and which (perhaps) to jettison.

## Analytic Framework

As depicted in Figure 1, the analytic framework for behavioral dietary interventions extends from existing household and individual dietary practices to the ultimate health outcome of interest, cancer prevention. Our evidence review will stop short of the health outcome per se and focus instead on the intermediate outcomes of dietary and biomarker change. The link between dietary intake and cancer has been extensively studied through epidemiologic research.

Figure 1. Hypothesized Analytical Framework: Efficacy of Behavioral Dietary Interventions to Reduce Cancer Risk

With the seminal publication of Doll and Peto (1981) on the causes of cancer, the estimate that approximately 30 percent of all cancers (with a range of 10 percent to 80 percent) could be prevented through diet became commonly accepted.^1^ Willett (1998) revised these estimates,^6^ pointing to a 35 percent preventive potential of diet, with a much narrower confidence interval than that of Doll and Peto. The known and potential role of diet in various cancer sites has been reviewed repeatedly, most extensively in the expert report published by the World Cancer Research Fund (WCRF);^7^ it reviews the growing body of epidemiologic evidence of relationships among individual foods, specific dietary nutrients and nonnutrients, and the occurrence of cancer. It projects that, globally, between one-third and one-half of all cancers of the mouth and pharynx, pancreas, breast, and liver are preventable by diet. The "preventable" estimates are higher for esophageal cancers and reach between two-thirds and three-quarters for all cancers of the stomach, colon, and rectum.

The majority of this evidence is based on observational epidemiologic studies relating self-selected diets to cancer risk. In the search for causes of cancer, the role of diet was initially considered important primarily in the context of artificial colors, sweeteners, and preservatives. More recently, attention has turned to issues relating to fat, fruits and vegetables, and fiber. According to the WCRF report, the most convincing data support the protective effect of fruits and vegetables. Evidence suggests a "possible link" between cancer and low dietary fiber as well as cancer and high total fat intake.^7^

Clinical trials on dietary influences on carcinogenesis have been restricted largely to single-substance supplements in nonfood form, such as antioxidants (vitamins C, A, and E; beta carotene; selenium). Among the best-known investigations are the Linxan Study in China on a population at high risk of esophageal cancer,^8^ the beta carotene trials in the United States (the carotene and retinol efficacy trial, CARET, among long-term smokers and people exposed to asbestos)^9^ and Finland (ATBC study),^10^ and the Physicians' Health Study.^11^ These nutrient agents have been generally introduced in pill or placebo form in multifactorial studies among populations at high risk of either occurrence (e.g., persons having polyps or living in areas with extremely high incidence rates) or recurrence (e.g., persons with skin cancer). They are introduced late in life and generally have intervention periods of less than a decade. Some of these studies have yielded surprising results both in the amount of time needed to see an effect (much shorter than expected a priori) and in the direction of effect (some trials showed an increase in risk with supplementation).

Two recent randomized trials failed to support the fiber-adenoma hypothesis. One trial provided wheat-bran fiber supplements,^12^ and the other intervened with intensive counseling to increase fiber, decrease fat, and increase fruits and vegetables.^13^ Neither study reported significant intervention effects on recurrence of colorectal adenomas over a 3-year follow-up period.

The inconsistent findings of many diet-cancer observational studies as well as clinical trials raise questions as to the strength of the association, but they may also reflect biases inherent in this type of research. Dietary intake is typically homogeneous among individuals in a specific population and may be confounded by other environmental exposures. Systematic errors associated with dietary assessment methodology are well known. In clinical intervention trials, the wrong active ingredient may have been singled out and may actually be only a marker of the true active ingredient or combination of ingredients in food.^6^ Possible explanations for null findings include the potential that nutrition factors are more relevant at earlier stages of the carcinogenesis process, and the fact that length of follow-up may be inadequate for the outcome of interest.

In the analytic framework, an individual's pre-intervention dietary intake (Time 1) is influenced by family and household practices (immediate environment) and by the broader environmental factors of food access, culture, and policy. The environmental influences come into play throughout the causal pathway and thus are depicted across the breadth of the diagram. Different categories of interventions, shown as occurring between individual dietary intake and various mediators, can influence dietary change. The ultimate impact of these interventions on dietary change depends greatly on the degree to which they are implemented as planned and on their intensity (or dose). The interventions are likely to first affect psychosocial and cognitive mediating factors such as knowledge and a wide range of attitudes and beliefs derived from health behavior theory. Many psychosocial and cognitive mediators affect the degree to which interventions are received and accepted by the individual. In dietary intervention studies, these factors are often measured to determine whether the intervention is having an impact on intermediate or intervening variables associated with dietary change and to assess which mediators may be most associated with change in outcome measures.

The combined effect of intervention (and its intensity) and psychosocial and cognitive mediators then influences individual dietary intake at Time 2. Measurement challenges make it very difficult to assess "truth" when it comes to self-reported dietary intake (the basis of nearly all dietary assessment measures). Therefore, in dietary intervention studies, biomarkers are increasingly measured in an attempt to validate reported dietary intake.

For dietary interventions to have an impact on long-term cancer risk reduction, they are assumed to promote maintenance of dietary change in compliance with the NCI recommendations over an extended period of time. However, few intervention programs include a long-term maintenance component, and even fewer measure the degree to which positive changes are maintained after the intensive intervention is over.

Ultimately dietary change, maintained over time, should lead to a decreased risk of certain cancers, based on our understanding of the epidemiologic literature. Adverse outcomes of dietary change interventions (shown between mediators and Time 2 dietary intake but possible at other times) are quite rare, but reports have appeared of failure to thrive among infants and young children as a result of excessive fat restriction by parents. With any dietary intervention comes the concern (particularly among young women) that, given the right mix of psychosocial and cognitive factors, dietary restrictions could escalate to eating disorders.

In addition to affecting cancer risk, dietary interventions may lead to changes in other health conditions. The prudent diet advocated to prevent heart disease is low in saturated fat and cholesterol and relatively high in complex carbohydrates, including fruits and vegetables.^4^ It is similar to the diet recommended for cancer prevention.^3^ This diet has been advocated for 40 years in various forms to prevent heart disease. Denke (1995) ^14^ reviewed the effectiveness of this diet to lower blood cholesterol in individuals at usual risk and at high risk for coronary heart disease (CHD). In the individual trials, cholesterol reduction ranged from 4 percent to 17 percent, with greater reductions in the high-risk groups. Cholesterol reductions were lower but often statistically significant in the community intervention trials, ranging from 1 percent to 11 percent. These studies suggest that dietary change consistent with that advocated for the prevention of cancer can be achieved and sustained with appropriate interventions.

## Primary Objectives and Scope of the Evidence Report

An evidence report on the effectiveness of dietary interventions to reduce cancer such as this one-commissioned by NCI from the Research Triangle Institute-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) through the Evidence-based Practice Program of the Agency for Healthcare Research and Quality -- will provide the foundation for creating and disseminating best public health and clinical practices. Many public health programs and services now incorporate dietary interventions aimed at chronic disease risk reduction, but they struggle with decisions about how to spend scarce resources in a way that maximizes dietary change. Clinical counseling to promote a healthy diet is one of the clinical preventive services addressed by the U.S. Preventive Services Task Force (USPSTF), which is now under the aegis of AHRQ and supported by the RTI-UNC EPC. An evidence report on this topic should further AHRQ's general interest in behavioral counseling of patients, medical informatics, and the design of effective educational tools and behavioral interventions.^15^ Findings from this report can also help AHRQ extend knowledge about the role of clinicians in promoting behavioral interventions to reduce morbidity and mortality from various chronic diseases.

In addition to providing the foundation for practice guidelines to be developed by others, an evidence report serves an important role in identifying promising areas for continued research as well as holes or gaps that may become the basis for future funding priorities. A particular focus on underserved groups will help to identify whether (a) these groups are currently being included in the interventions tested, (b) intervention programs meet their particular needs and interests, (c) effectiveness measures are appropriate for the target audiences, and (d) intervention effectiveness differs among different subgroups when different intervention strategies are implemented.

## Key Clinical Questions

The Request for Proposal (RFP) posed four separate key questions. One item specified a multipart typology of behavioral interventions ranging from individual-directed to community-based projects as well as multistrategy endeavors.^16-18^ The typology described by Rimer (1995) ^16^ classifies interventions into eight categories: individual-directed (including school, community and worksite settings, and health care settings), system- and physician-directed interventions, access-enhancing interventions, policy-level interventions, media campaigns (including broadcast and print media and point-of-purchase interventions), community-based interventions, multistrategy interventions, and tailored interventions or interventions using emerging technologies. The RFP explicitly drew attention to interventions based on emerging technologies (such as communications and information technologies). In conceptualizing our approach to this evidence report, we are restating the questions in a somewhat more streamlined way as follows:

1. Is there evidence that one type of intervention or combination of interventions, using a broad typology of behavior interventions and including emerging technologies and approaches, is more effective than another for helping individuals or groups modify their diet to consume more fruits and vegetables and less fat?
2. What is the evidence by subgroup (e.g., African American, Hispanic, Asian American, Native American) and for males and females within these groups?
3. What conclusions (if any) can be reached about the cost-effectiveness of these types of interventions?

These key questions generated additional issues involving intervention design and measurement. In critiquing and synthesizing the literature on dietary interventions, we gave these special attention, as discussed in Chapters 2 and 3.

Our review of the literature made it clear that, although the typology of interventions described by Rimer and others represents an excellent characterization of the breadth and scope of existing and needed research in the area, the vast majority of published manuscripts fall into a very limited number of the categories described. This fact dictated that we employ different grouping strategies in our analysis and summary of the literature.

## Technical Expert Advisory Group (TEAG)

AHRQ guidelines required identification of technical experts in the field of dietary interventions related to cancer. The Technical Expert Advisory Group (TEAG) was expected to contribute to advancing AHRQ's broader goals of (a) creating and maintaining science partnerships and public-private partnerships and (b) meeting the needs of an array of potential customers and users of its products. Thus, it was both an additional resource and a sounding board throughout the project. Our TEAG comprised eight individuals who provided expertise from (a) clinical and public health practice in the area of dietary interventions, (b) private or quasi-public consumer organizations, and (c) the perspective of likely users of this EPC report such as health plans concerned with quality of care and value purchasing, or business coalitions.

We conducted five conference calls with TEAG members. To ensure robust, scientifically relevant work, the TEAG was called on to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. In the early stages of the project, TEAG members assisted us with refining the key questions and analytic framework and provided guidance on the scope of the literature to be included. Later in the project, the TEAG provided guidance on inclusion and exclusion criteria for the literature review, the application of meta-analysis and other analytic strategies, and methods for grouping studies to facilitate comparison. See Appendix B for more detail about the TEAG.

Apart from the TEAG, we also identified external peer reviewers, numbering an additional nine individuals. AHRQ and NCI selected the TEAG members and peer reviewers from a list of nominees. The roster of individual experts and organizations serving as reviewers is found in Appendix C.

## Organization of the Report

The remainder of this evidence report is organized in the following sections. In this Volume 1, Chapter 2 provides details about our literature search and review methodology. Specifically included are the analytical framework for our key clinical questions and our approaches to conducting the systematic review, abstracting data from articles, maintaining quality control, applying a quality rating system to individual articles, and similar details. Chapter 3 provides the results of our analyses, including a meta-analysis for dietary fat outcomes. Chapter 4 provides the concluding discussion, and Chapter 5 offers our recommendations for a research agenda on behavioral dietary interventions specific to cancer reduction. Chapter 6 provides the references cited in the body of the evidence report.

Volume 2 contains our Evidence Tables (Chapter 7) and supporting information. Finally, the complete list of literature considered and used in developing the evidence report (including all articles reviewed in the literature search and all references citations in Chapters 1-7) appears in the bibliography (Chapter 8). The appendices provide acknowledgments (Appendix A), information on our TEAG (Appendix B), the peer reviewers for this report (Appendix C), and our Data Abstraction Form (Appendix D) and Quality Rating Form (Appendix E).