# Appendix E. Glossary of Abbreviations

~: approximately

% energy: percentage of energy (total kcals or MJ)

A: Asian American

adj: adjusted (adjusted for)

ANCOVA: analysis of covariance

ANOVA: analysis of variance

B: Black

b/w: between

base: baseline

beh: behavior

carb: carbohydrates

chol: cholesterol

chng: change

comp: comparison

con: control

CVD: cardiovascular disease

d: day

dep: dependent

diff: difference

ed: education

exerc: exercise

EFNEP: Expanded Food and Nutrition Education Program

F: female

FFQ: food frequency questionnaire

F&V: fruits and vegetables

f/u: follow-up

fam: family

g: gram

grp: group

H: Hispanic

hr (hrs): hour (hours)

IDDM: insulin-dependent diabetes mellitus

indiv: individual

info: information

intent. to treat: intention to treat

intv: intervention

LDL-C: low-density lipoprotein cholesterol

M: male

MANCOVA: multiple analysis of covariance

MANOVA: multiple analysis of variance

med: medication

mg/dL: milligrams per deciliter

MI: myocardial infarction

mo (mos): month (months)

mmol/L: millimoles per liter

µmol/L: micromoles per liter

N: Native American

NIDDM: non-insulin-dependent diabetes mellitus

n.s.: not significant

NR: not reported

nutr: nutrition

O: other race

p:s: polyunsaturated to saturated fat ratio

part: participation

pop: population

prot: protein

pts: patients

RCT: randomized controlled/clinical trial

RD: registered dietician

reg: regression

ret: retention

RN: registered nurse

sat: saturated

sd: standard deviation

se: standard error

sig: significant/significance

soc: social

TC: total cholesterol

tot tx: total treatment

unsat: unsaturated

var: variable

veg: vegetable

W: White

w/i: within

wk (wks): week (weeks)

yr (yrs): year (years)