# Appendix D. Description of Evidence Tables

## General organization and information

The Evidence Tables are organized by intervention setting and are presented in four sections: school, health care (this section includes interventions conducted in a health care setting and interventions for which subjects were recruited from healthcare settings), worksite, and community/other (this section includes interventions conducted in homes, churches, grocery stores, and communities). Abbreviations used in the Evidence Tables, and in this description of the Evidence Tables, are defined in the Glossary that follows this description.

## Author/year

This column provides the RTI/UNC EPC identification number for each article, the first three authors' last names, and the year of publication. In the case of multiple articles reporting the results from the same study, the results are presented in one entry, with all supporting articles cited in the "author/year" column. If applicable, the name of the study/intervention is also provided in this column.

## Study setting and population

The following information is provided for all articles in the tables:

- Setting:
- a description of the setting of the intervention (with the site/subject recruitment strategy provided in parentheses)

- Gender:
- a description of whether the study included males, females, or both

- Age:
- a description of the age range of subjects (if provided) or the mean age of subjects (if the range is not provided) at baseline

- Race:
- a description of all racial/ethnic groups included in the study

- Risk:
- an indication of whether the sample was at risk for (or diagnosed with) a particular condition (e.g., "CVD risk") or whether the subjects were derived from the general population

In addition, if the study population included primarily low-income subjects, the notation "low-income pop" is included in this column. If the study was conducted outside of the United States, the country is provided in this column. If statistical analyses were conducted separately for demographic subgroups (e.g., results presented separately for males and females), this column includes a brief description of which subgroups are presented separately for which results.

## Study design

A brief description of the study design is provided at the top of the column (e.g., "RCT"). Then a longer description of how sites/subjects were assigned to treatment conditions, the number of arms of the study, and other relevant design characteristics (e.g., matching, use of subsamples) are provided.

## Sample size and retention rates

This column includes the following information for all articles:

- Participation rate:
- the percentage of eligible subjects who either participated in the study or provided baseline data

- Baseline sample size:
- the number of subjects who provided baseline data (which is not necessarily the sample size used in the statistical analyses)

- Follow-up sample size:
- the number of subjects who provided data at each follow-up point of the study (which is not necessarily the sample size used in the statistical analyses)

- Retention rate:
- the percentage of subjects who provided baseline data and also provided follow-up data

- Comparison of drop-outs:
- statistically significant differences between subjects lost to follow-up (or not completing the intervention) and subjects who remained in the study

Participation rates, sample sizes, and retention rates are provided for sites (if relevant) and subjects. In addition, they are provided for intervention group(s) and control groups if reported. If not reported individually for treatment groups, the rates/numbers are presented for the entire sample, with "total" noted in parentheses. Follow-up sample sizes are presented for all follow-up points included in the study. Unless otherwise stated, retention rates are presented only for the first follow-up point of the study. Among the few articles reporting results for cross-sectional "waves" of data (rather than employing a true longitudinal design), the wording has been changed to "wave 1," "wave 2," etc., rather than "baseline" and "follow-up."

## Intervention received

This column describes the intervention received by the intervention group and the conditions experienced by the control group. If more then one intervention group was included in the study, this is indicated in parentheses next to "Intervention group," and the differences in the interventions received by the intervention groups are noted under the "intervention components" subheading. The following information is included for the intervention group(s):

- Intervention components:
- a brief description of the major features of the intervention (e.g., counseling, lectures, activities, exercise classes), including non-dietary components, reported in the article

- Intervention delivery:
- a list of all persons involved in the delivery of the intervention (e.g., RD, trained lay educators)

- Special features:
- an indication of whether the intervention included small-group learning, social-support components, family components (e.g., inviting spouses of the intervention participants to take part in activities), cultural/ethnic specificity, and individually tailored components

- Nutritional message:
- a brief summary of the main nutrition message taught to the participants in the intervention (e.g., decrease dietary fat, increase fruits and vegetables [F&V])

For the control group, a brief description of the intervention components is provided.

## Duration of intervention

This column includes all information on the duration of the intervention reported in the article (e.g., number of contacts, frequency of contacts, length of contacts, time between contacts), broken down (when reported) into intervention components. If the intervention included a maintenance component (or follow-up activities other than data collection), a brief description of this element is provided.

## Duration of follow-up

The length of time until follow-up data collection (usually from baseline data collection) is provided in this column. The duration of follow-up is reported for each follow-up data collection point.

## Fruits and Vegetables: Measurement

The following information is included in this column:

- Variables:
- a brief list of the fruit and vegetable (F&V) outcomes (and units, when reported) is included in the Evidence Tables; results for up to three relevant outcomes are reported for F&V

- Other variables analyzed:
- a list of any other F&V outcomes for which results are reported in the full article but are not included in the Evidence Tables

- Instrument:
- a description of the methodology used to measure the F&V outcomes (e.g., dietary recalls, food frequency questionnaires [FFQs]), including the number of days (if reported) for dietary recalls and food records, and the number of items (if reported) for FFQs or other questionnaires

- Statistics:
- a description of the statistical analysis procedures used to determine the significance of the intervention (wording closely follows the description in the article)

## Fruits and Vegetables: Results

This column presents the statistical results for up to three relevant F&V outcomes. The outcome is in boldface type, and the statistics reported in the column are described in parentheses next to the boldfaced outcome (e.g., "mean and sd"). The notation "sd/se NR" indicates that the standard deviation (sd) or standard error (se) was not reported (NR) in the article. Relevant statistics are presented for each reported data collection point for each treatment group. The sample sizes used in the analyses are presented in parentheses or brackets for each treatment group.

- Significant effects:
- a brief summary of all reported p values (if the actual p value is not reported in the article, the upper limit is provided [e.g., "p < 0.05"]) for all analyses reported in the article

- Intention to treat:
- a brief description of the manner in which the authors addressed the "intention to treat" principle in their analyses (if reported)

## Author/year

The last names of the first three authors and the year of publication are reported in this column.

## Dietary fat: measurement

The following information is included in this column:

- Variables:
- a brief list of the dietary fat outcomes (and units, when reported) included in the Evidence Tables; results for up to three relevant outcomes are reported for fat, including total fat (either as percentage of energy from fat or in grams), saturated fat (either as percentage of energy from fat or in grams), foods used as proxy measures of fat (e.g., fried foods), and/or fat-related behaviors (e.g., trimming fat off meat, drinking skim milk)

- Other variables analyzed:
- a list of any other dietary fat outcomes for which results are reported in the full article but are not included in the Evidence Tables

- Instrument:
- a description of the methodology used to measure the fat outcomes (e.g., dietary recalls, FFQ), including the number of days (if reported) for dietary recalls and food records, and the number of items (if reported) for FFQs or other questionnaires

- Statistics:
- a description of the statistical analysis procedures used to determine the significance of the intervention (wording closely follows the description in the article)

## Dietary fat: results

This column presents the statistical results for up to three relevant dietary fat outcomes. The outcome is in boldface type, and the statistics reported in the column are described in parentheses next to the boldfaced outcome (e.g., "mean and sd"). The notation "sd/se NR" indicates that the standard deviation (se) or standard error (se) was not reported (NR) in the article. Relevant statistics are presented for each reported data collection point for each treatment group. The sample sizes used in the analyses are presented in parentheses or brackets for each treatment group.

- Significant effects:
- a brief summary of all reported p values (if the actual p value is not reported in the article, the upper limit is provided [e.g., "p < 0.05"]) for all analyses reported in the article

- Intention to treat:
- a brief description of the manner in which authors addressed the "intention to treat" principle in their analyses (if reported)

## Other dietary outcomes

This column indicates whether a significant intervention effect was found for outcomes related to either fiber (including actual fiber intake, grain intake, wheat intake, or intake of individual foods such as breads or cereals) or calcium (including actual calcium intake, dairy intake, or intake of individual foods such as milk or cheese). The outcome is listed, and a brief indication of whether an intervention effect was reported in the article is provided.

## Biochemical indicators: measures

The following information is included in this column:

- Variables:
- a brief list of the biochemical outcomes (and units, when reported) included in the Evidence Tables; results for up to three relevant outcomes are reported, including total cholesterol, LDL-C, and carotenoids

- Other variables analyzed:
- a list of any other biochemical outcomes for which results are reported in the full article but are not included in the Evidence Tables

- Instrument:
- a description of the methodology used to measure the biochemical outcomes, including whether the sample was obtained with the subject in the fasting state (if reported), how the sample was analyzed (if reported), and information about laboratory quality control procedures (if reported)

- Statistics:
- a description of the statistical analysis procedures used to determine the significance of the intervention (wording closely follows the description in the article)

## Biochemical indicators: results

This column presents the statistical results for up to three relevant biochemical outcomes. The outcome is in boldface type, and the statistics reported in the column are described in parentheses next to the boldfaced outcome (e.g., "mean and sd"). The notation "sd/se NR" indicates that the standard deviation (sd) or standard error (se) was not reported (NR) in the article. Relevant statistics are presented for each reported data collection point for each treatment group. The sample sizes used in the analyses are presented in parentheses or brackets for each treatment group.

- Significant effects:
- a brief summary of all reported p values (if the actual p value is not reported in the article, the upper limit is provided [e.g., " p < 0.05"]) for all analyses reported in the article

- Intention to treat:
- a brief description of the manner in which authors addressed the "intention to treat" principle in their analyses (if reported)

## Behavioral mediators

This column indicates whether a significant intervention effect was found for behavioral mediators (or antecedents) related to dietary intake (including attitudes, self-efficacy, knowledge, intentions, stage of change, perceived social support, and other relevant outcomes). The outcome is listed, and a brief indication of whether an intervention effect was reported in the article is provided.

## Quality score

The quality score assigned to each article is a numerical value ranging from 0 to 100. This score is based on the following factors:

- the quality of the description of the intervention (including relevant details about the setting, components, delivery, duration, and intensity of the intervention)
- the quality of the description of the study population, recruitment strategy, and inclusion/exclusion criteria
- the quality of the description of the variable measurement and statistical analysis procedure
- whether the intervention was theoretically based
- whether the research design was random allocation of individuals/units to treatment groups
- the sample size
- the duration of follow-up
- the retention rates
- the description and validity of the dietary assessment tool
- whether changes in biochemical outcomes were explored
- whether analysts were blind to the assignment of treatment groups
- the generalizability of the results (based on the representativeness of the sample and the practicality of the intervention)