# Appendix C. Quality Rating Form

Category I. Description of the study: (30 points) | | Points (circle 1 for each item)
1. | Was the description of the intervention setting, components, delivery, duration, and intensity
| (a) Low quality (unclear, many details missing) | 0
| (b) Medium quality (pretty clear, most details provided) | 5
| (c) High quality (very clear, all essential details provided) | 10
2. | Was the description of the study population (i.e., gender, ethnicity, income), recruitment strategy, and inclusion/exclusion criteria
| (a) Low quality (unclear, many details missing) | 0
| (b) Medium quality (pretty clear, most details provided) | 5
| (c) High quality (very clear, all essential details provided) | 10
3. | Was the description of the variable measurement and statistical analysis procedure
| (a) Low quality (unclear, many details missing) | 0
| (b) Medium quality (pretty clear, most details provided) | 5
| (c) High quality (very clear, all essential details provided) | 10
Subtotal (Category I):

Category II. Quality of the study design and methodology (70 points) | | Points (circle 1 for each item)
4. | Was the intervention theoretically based
| (a) No (include not reported) | 0
| (b) Yes | 5
5. | Was the research design
| (a) Non-equivalent comparison group or not reported | 0
| (b) Random allocation of individuals or units to intervention vs. control group | 10
6. | Was the sample size of the intervention group at baseline
| (a) Less than 50 (or not reported) | 0
| (b) 50-100 | 5
| (c) More than 100 | 10
7. | Was the total duration of follow-up
| (a) Less than 3 months | 0
| (b) 3 to 6 months | 3
| (c) 6 months to 1 year | 6
| (d) More than 1 year | 10
8. | Was the loss at follow-up 1 in both the intervention and control groups
| (a) More than 30% (or not reported)? | 0
| (b) 20-30% | 5
| (c) Less than 20% | 10

Quality Rating Form (continued) | | Points (circle 1 for each item)
9. | Was the dietary assessment tool clearly described and the validity of the tool specified or referenced?
| (a) Neither clearly described nor validity addressed (include not reported) | 0
| (b) Tool was clearly described, but validity was not mentioned | 3
| (c) Tool was clearly described and validity was specified/referenced | 5
10. | Were changes in biochemical outcomes explored in the study
| (a) No (include not reported) | 0
| (b) Yes | 5
11. | Were analysts blind to the assignment of intervention and control groups?
| (a) No (include not reported) | 0
| (b) Yes | 5
12. | Is the generalizability (i.e., applicability to the general population) of the results
| (a) Low (study sample not representative of general population, or intervention extremely unrealistic/expensive) | 0
| (b) Medium (study sample fairly representative) | 5
| (c) High (study sample representative of general population) | 10
Subtotal (Category II):
Total Quality Points: