# Appendix B. Data Abstraction Form

A. Study Identification
1. Review (circle one): [a] abstractor rating [b] reconciled rating
2a. Abstraction date: __ __/__ __ /1999
2b. Reconciliation date: __ __/ __ __/1999
3a. Article ID no.: __ __ __ __
3b. Abstractor initials: __ __ __
4a. Authors(last names of first three authors):
4b. Year of article: 19 __ __
5. Name for the study (if provided): (e.g., PRAISE, Women's Health Initiative)
6. Provide citations (last name of first three authors and year) for any supporting articles (i.e., multiple articles from the same study/author that are necessary to report pieces of information missing from the current article):
Items requiring resolution: (please list the item number and a brief description of any problematic or unclear items that require further attention by senior project staff)

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

B. | Screening Questions
| All articles will need to be screened for potential exclusion. Several articles are likely to be excluded because they do not meet our criteria. Examine the article for the following exclusion criteria, and circle "yes" for any of the following that apply: [here and in several questions below, the reader is told to circle "yes" but that's not possible. Does it mean to circle "the number in the "yes" column"? Or what? (And what does the number in the "yes" column mean?] | Yes
7. | No nutrition intervention (e.g., epidemiologic study with no intervention) Note: any dietary counseling or nutrition advice counts as an intervention | 1
8. | Review article without primary data | 1
9. | No measures of dietary fat intake or fruit and/or vegetable intake (see guidelines) | 1
| If "yes" was circled for #9, does the article include:
| a. Only behavioral mediators? (e.g., dietary knowledge, attitudes, beliefs, or intentions) | 1
| b. Only biochemical indicators of diet? (e.g., serum/blood lipids [cholesterol], ascorbic acid, carotenoids) | 1
10. | Baseline data study only (see guidelines) | 1
11. | Limited applicability
| a. Institutionalized population (Include studies on military personnel. Exclude studies on prisoners, nursing home residents, and other non-free-living individuals.) | 1
| b. Studies where diet was externally controlled (Exclude the study if meals were provided/prescribed for subjects.) | 1
| c. Study outside North America, Australia, or Europe | 1
| d. Study was on infants or reproductive health | 1
| e. Other (specify): | 1
12. | The study did not include a control/comparison group (see guidelines) | 1
13. | The total sample size at follow-up was fewer than 40 subjects | 1
If the article is excluded for any of these reasons, do not continue

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

C. | Intervention Characteristics (see guidelines) | Yes
14. | Theoretical frameworks used for intervention(s)
| (Circle "yes" for all that apply):
| a. Fishbein/Ajzen (theory of reasoned action)........................... | 1
| b. Health belief model................................................................. | 1
| c. Social cognitive theory/social learning theory....................... | 1
| d. Stages of change (transtheoretical theory).......................... | 1
| e. Enabling/Access Enhancing (PRECEDE model).................. | 1
| f. Other theory (specify):........................................................... | 1
| g. No theory reported................................................................. | 8
15. | Type of intervention (see guidelines) (Circle "yes" for all types of interventions that apply to the study. If more than one intervention group is included, circle intervention characteristics for each group separately.) | Yes
| a1. Individual-directed intervention | 1
| a2. Family-directed intervention | 1
| If the intervention is an individual or family intervention, circle all settings that apply
| a1. Healthcare..................................................................................
| a2. Worksite............................................................................. | 1
| a3. School................................................................................... | 1
| a4. Point-of-purchase............................................................................. | 1
| a5. Community............................................................................ | 1
| a6 Home..................................................................................... | 1
| a7. Other (briefly describe):....................................................................... | 1
| b. System/physician directed | 1
| c. Access-enhancing intervention | 1
| d. Policy intervention | 1
| e. Environmental intervention | 1
| f. Media campaign | 1
| If the intervention is a media intervention, circle all forms [not clear what is to be circled-the form itself or the "yes" column number?] that apply
| f1. Television......................................................................................... | 1
| f2. Radio................................................................................................ | 1
| f3. Newspaper...................................................................................... | 1
| f4. Other (specify:)................................................................................. | 1
| g. Community intervention | 1
| h. Tailored computerized intervention or emerging technologies | 1
16. | List the primary setting of the intervention (from #15 above, e.g., healthcare setting, school setting, environmental, media) (see guidelines)
17. | Describe the components of the intervention received by the intervention group(s) and control group (e.g., classes, types of instructional materials, one-on-one counseling, reducing prices of nutrition foods, offering low-fat choices in a cafeteria, exercise groups, stress management therapy) (see guidelines)

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

Group | Nutrition components | Collateral interventions
Intervention group:
Intervention group 2: (if applicable)
Control group:

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

18. | Who delivered the intervention received by the intervention group(s) and control group (e.g., dietician, physician, regular classroom teacher, clinical psychologist) (see guidelines)
18. | Intervention group:
18. | Intervention group 2(if applicable):
18. | Control group(if the control group received any intervention):

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

19. | Briefly describe the main nutrition message of the intervention (e.g., increase fruit and vegetable intake, decrease fat intake, follow a vegetarian diet) (see guidelines)
| Intervention group:
| Intervention group 2(if applicable):
| Control group(if the control group received any intervention):

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

C. Intervention Characteristics (continued)
20. | Special features of the intervention | Yes | No
| a. Did the intervention include a social support component (such as support groups either during the intervention or long-term)? If yes, briefly describe: | 1 | 0
| b. Did the intervention include a family intervention component (i.e., including the family/spouse/parent of the primary target of the intervention)? If yes, briefly describe: | 1 | 0
| c. Was the intervention specifically designed to provide individually tailored guidance/messages? (see guidelines) If yes, briefly describe: | 1 | 0
| d. Was the intervention designed to be culturally/ethnically specific? If yes, briefly describe: | 1 | 0
| e. Does the article report data on the cost of the intervention? | 1 | 0
21. | Describe the duration of intervention Include length, number of exposures, and any other information related to intensity). (see guidelines)
22. | Did the study report that a maintenance component was included in the intervention? (see guidelines) | Yes | No
| | 1 | 0
| If yes, briefly describe the format (e.g., support group, phone call reminders), the intensity (i.e., number of exposures), and the duration of the maintenance component:

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

D. | Population Characteristics (Indicate whether the study included, was restricted to, or conducted separate analysis for the following subgroups) | Included | Restricted to | Separate Analyses for
23. | Sex:
| a. Males.................................................................... | 1 | 2 | 3
| b. Females................................................................. | 1 | 2 | 3
| c. Sex not reported .................................................... | 8 | 8 | 8
24. | Age of participants
| a. (write in age range or other age descriptor included in the study): ______________________________ | 1 | 2 | 3
| b. Age not reported.................................................. | 8 | 8 | 8
25. | Racial/ethnic characteristics (circle for all ethnicities included)
| a. Black/African American....................................... | 1 | 2 | 3
| b. Hispanic or Latino................................................. | 1 | 2 | 3
| c. Non-Hispanic Whites........................................... | 1 | 2 | 3
| d. Asian/Asian Americans........................................ | 1 | 2 | 3
| e. Native Americans................................................. | 1 | 2 | 3
| f. Other (specify)..................................................... | 1 | 2 | 3
| g. Race/ethnicity not reported.................................. | 8 | 8 | 8
26. | Low-income populations
| a. (Circle if the study included, was restricted to, or conducted separate analyses for low-income populations, and briefly describe the population (e.g., Food Stamp participants, blue collar workers)_________________________________ | 1 | 2 | 3
| b. Income not reported............................................ | 8 | 8 | 8
27. | Country
| a. United States........................................................ | 1 | 2 | 3
| b. Canada................................................................. | 1 | 2 | 3
| c. Caribbean (specify country)................................ | 1 | 2 | 3
| d. Mexico.................................................................. | 1 | 2 | 3
| e. Europe (specify country)..................................... | 1 | 2 | 3
| f. Australia or New Zealand..................................... | 1 | 2 | 3
| g. Other (specify).................................................... | 1 | 2 | 3
| h. Country not reported............................................. | 8 | 8 | 8
Note: Remember that studies conducted outside North America, Australia, and Europe are excluded.

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

D. | Population Characteristics (continued) (Indicate whether the study included, was restricted to, or conducted separate analysis for the following subgroups) | Included | Restricted to | Separate Analyses for
28. | Risk status (circle for all risk groups included in the study) (see guidelines)
| a. General population......................................................... | 1 | 2 | 3
| b. High risk (e.g., undergoing treatment , family history of disease) | 1 | 2 | 3
| b1. If high risk, specify type of condition:
| a. Cancer............................................................. | 1 | 2 | 3
| b. CVD................................................................. | 1 | 2 | 3
| c. NIDDM............................................................. | 1 | 2 | 3
| d. Other (specify)..................................................... | 1 | 2 | 3
| b2. If high risk, how was risk determined?
| a. Family history of the condition | 1 | 2 | 3
| b. EARLY risk factor for disease identified specify risk factor: _________________________ | 1 | 2 | 3
| c. Subjects currently have condition | 1 | 2 | 3
| d. Subjects previously had condition | 1 | 2 | 3
| e. Other (briefly describe):________________________________ | 1 | 2 | 3
| f. Not reported | 8 | 8 | 8
| c. Risk status not reported........................................... | 8 | 8 | 8

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

E. Design and Analysis Characteristics
29. | Research design (see guidelines) (circle all that apply) | Yes
| a. Random assignment of individuals into intervention or control......................... | 1
| b. Random assignment of units (e.g., clinics, schools, communities) into intervention or control........................................................................................ | 1
| c. Other randomized design (briefly describe):............................................................. | 1
| d. ["d" not aligned] Non-equivalent comparison group design (briefly describe):.............................. | 1
| e. Not reported...................................................................................................... | 8
30. | Unit of analysis in the study (circle all that apply) | Yes
| a. Individuals.......................................................................................................... | 1
| b. Units (e.g., schools, worksites) (briefly describe).............................................. | 1
31. | Length of time from baseline until: (e.g., immediate, ____days/weeks/months, other, NR)
| a. Follow-up 1:
| b. Follow-up 2 (if applicable):
| c. Follow-up 3 (if applicable):

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

32. | Recruitment and retention rates (Note: If information not provided, write "NR" in the appropriate cell. If information not applicable, write "n/a" in the appropriate cell.) (see guidelines) | Intv. Group | Intv. Group 2 (if appl) | Control Group
| a. Participation rate (% of subjects originally assigned to groups who completed participation in the intervention)
| b. Provide the % (or number) of subjects who were retained in the study at each follow-up period
| b1. Number of subjects at baseline
| b2. Number (or %) of subjects at follow-up 1
| b3. Number (or %) of subjects at follow-up 2
| b4. Number (or %) of subjects at follow-up 3

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

33. | Describe any weaknesses in the study design or population characteristics that you noticed (i.e., factors that limit generalizability, significant differences between the intervention and control groups at baseline, other problems, etc.)

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

F. Study Outcomes (see guidelines)
34. | Summary of measurement findings: Follow priorities listed in guidelines and indicate whether significant effects were found for the following outcomes. Detailed results for outcomes a-d will be abstracted in detail in the following sections. The results for outcomes e- f will only be summarized in this table. | | Sig. | n.s.
| a. | Fruit and/or vegetable intake
| | Measure 1 (briefly list outcome): | 1 | 2
| b. | Fat intake
| | Measure 1 (briefly list outcome): | 1 | 2
| | Measure 2 (briefly list outcome): | 1 | 2
| | Measure 3 (briefly list outcome): | 1 | 2
| c. | Biochemical indicators
| | Measure 1 (briefly list outcome):[not aligned] | 1 | 2
| | Measure 2 (briefly list outcome): | 1 | 2
| | Measure 3 (briefly list outcome): | 1 | 2
| d. | Other dietary outcomes
| | Measure 1 (briefly list outcome): | 1 | 2
| | Measure 2 (briefly list outcome): | 1 | 2
| | Measure 3 (briefly list outcome): | 1 | 2
| e. | Behavioral mediators
| | Dietary knowledge (briefly list outcome): | 1 | 2
| | Dietary attitudes (briefly list outcome): | 1 | 2
| | Self-efficacy related to diet (briefly list outcome): | 1 | 2
| | Stages of change related to diet (briefly list outcome): | 1 | 2
| | Other behavioral mediators (briefly list outcome): | 1 | 2
| f. | Physical activity (briefly list outcome): | 1 | 2
| g. | Other physiologic outcomes (associated with CVD or cancer) explored
| | Measure 1 (briefly list outcome): | 1 | 2
| | Measure 2 (briefly list outcome): | 1 | 2
| | Measure 3 (briefly list outcome): | 1 | 2
| | Measure 4 (briefly list outcome): | 1 | 2
| | Measure 5 (briefly list outcome): | 1 | 2

Instructions for abstracting statistical results: The following pages elicit information about the actual statistics used to determine the efficacy of the intervention at changing dietary outcomes. Outcomes a-d (from the table above) will be abstracted in detail. Up to three measures may be abstracted for each outcome. Only the following measures should be abstracted (if reported).

Fruits and vegetables: Only total intake of fruits and vegetables

Dietary fat: Only total fat intake, saturated fat intake, index of fat consumption, index of fat-related behaviors, individual fat-related behaviors, or individual foods used as proxy indicators of fat intake. Only abstract up to three of these measures.

Biochemical indicators: Only total cholesterol, low-density lipoprotein (LDL) cholesterol, or total carotenoids

Other dietary outcomes: Only calcium intake (or dairy intake) or fiber intake (or whole foods used as proxy indicators of fiber)

F. Study Outcomes (continued)
35a. | Fruit and vegetable intake: | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [a] | servings per day
  [b] | grams per day
  [c] | other (specify):
2. | Did the fruit and vegetable outcome include potatoes? (specify if only some forms of potatoes were included)
  0 Yes | 1 No | 8 Not reported
  Briefly describe any other special exclusions related to the fruit/vegetable outcome:
3. | Name of instrument used to collect fruit and vegetable information:
4. | Type of instrument: (check all that apply)
  [a.] | Food frequency/checklist (list number of items included) : __ __ items
  [b] | 24-hour recall (list number of days used): __ __days
  [c] | Food record (list number of days used): __ __days
  [d] | History
  [e] | Food behavior
  [f] | Other (specify:)
  [g] | Not reported
5. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
6. | Reliability (or internal consistency) of dietary instrument
  a. | Did the study provide information about the reliability of the dietary instrument? [1] yes [0] no
  | If "yes," fill in reliability information below:
  | 0.__ __ (Circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):
7. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
Findings for Fruit and Vegetable Intake
8. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
9. Statistics (see guidelines for instructions)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in F&V intake at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ [here and later, what does superscript 1 refer to?] | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fruit and vegetable intake at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fruit and vegetable intake at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
10. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
36a. | Fat intake or fat-related behavior -- Measure #1 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | total fat - grams per day
  [b2] | total fat - % of total calories/energy
  [b3] | total fat - other units (briefly describe):
  [b4] | saturated fat - grams per day
  [b5] | saturated fat - % of total calories/energy
  [b6] | saturated fat - other units (briefly describe):
  [b7] | index of fat consumption (briefly describe):
  [b8] | scale/index of fat-related behaviors (briefly describe):
  [b9] | individual fat-related behaviors (specify):
  [b10] | individual food used as proxy for fat intake (specify):
  [b11] | other units (specify):
2. | Name of instrument used to collect dietary fat information:
3. | Type of instrument (check all that apply):
  [a] | Food frequency/checklist (list number of items included): _____ items
  [b] | 24-hour recall (list number of days used): __ __ days
  [c] | Food record (list number of days used): __ __ days
  [d] | History
  [e] | Food behavior scale/items (e.g., low-fat milk, taking skin off chicken)
  [f] | Other (specify:)
  [g] | Not reported
4. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
5. | Reliability (or internal consistency) of dietary instrument:
  a. | Did the study provide information about the reliability of the dietary instrument? [1] yes [0] no
  | If "yes," fill in reliability information below:
  | 0.__ __ (circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):

Findings for Fat Intake -- Measure 1
6. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
7. | Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
8. | Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2(if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
9. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
36b. | Fat Intake or Fat-Related Behavior -- Measure 2 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | total fat - grams per day
  [b2] | total fat - % of total calories/energy
  [b3] | total fat - other units (briefly describe):
  [b4] | saturated fat - grams per day
  [b5] | saturated fat - % of total calories/energy
  [b6] | saturated fat - other units (briefly describe):
  [b7] | index of fat consumption (briefly describe):
  [b8] | scale/index of fat related behaviors (briefly describe):
  [b9] | individual fat-related behaviors (specify):
  [b10] | individual food used as proxy for fat intake (specify):
  [b11] | other units (specify):
Note: Complete items 2-5 only if different from Dietary Fat Measure 1
2. | Name of instrument used to collect dietary fat information:
3. | Type of instrument (check all that apply):
  [a] | Food frequency/checklist (list number of items included): _____ items
  [b] | 24-hour recall (list number of days used): __ __ days
  [c] | Food record (list number of days used): __ __ days
  [d] | History
  [e] | Food behavior scale/items (e.g., low-fat milk, taking skin off chicken)
  [f] | Other (specify:)
  [g] | Not reported
4. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
5. | Reliability (or internal consistency) of dietary instrument:
  a. | Did the study provide information about the reliability of the dietary instrument? [1] yes [0] no
  | If "yes," fill in reliability information below:
  | 0.__ __ (circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):

Findings for Fat Intake -- Measure 2
6. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
7. | Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
8. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at baseline. Provide the sample size, statistic reported, and p value.Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at follow-up 1. Provide the sample size, statistic reported, and p value.Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at follow-up 2. Provide the sample size, statistic reported, and p value.Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
9. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes
36c. | Fat Intake or Fat-Related Behavior -- Measure 3 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | total fat - grams per day
  [b2] | total fat - % of total calories/energy
  [b3] | total fat - other units (briefly describe):
  [b4] | saturated fat - grams per day
  [b5] | saturated fat - % of total calories/energy
  [b6] | saturated fat - other units (briefly describe):
  [b7] | index of fat consumption (briefly describe):
  [b8] | scale/index of fat related behaviors (briefly describe):
  [b9] | individual fat-related behaviors (specify):
  [b10] | individual food used as proxy for fat intake (specify):
  [b11] | other units (specify):
Note: Complete items 2-5 only if different from Dietary Fat Measure 1
2. | Name of instrument used to collect dietary fat information:
3. | Type of instrument (check all that apply):
  [a] | Food frequency/checklist (list number of items included): _____ items
  [b] | 24-hour recall (list number of days used): __ __ days
  [c] | Food record (list number of days used): __ __ days
  [d] | History
  [e] | Food behavior scale/items (e.g., low-fat milk, taking skin off chicken)
  [f] | Other (specify:)
  [g] | Not reported
4. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
5. | Reliability (or internal consistency) of dietary instrument:
  a. | Did the study provide information about the reliability of the dietary instrument? [1] yes [0] no
  | If "yes," fill in reliability information below:
  | 0.__ __ (circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):

Findings for Fat Intake -- Measure 3
6. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
7. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
8. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in fat intake at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
9. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
37a. | Biochemical Indicators of Dietary Intake -- Measure 1 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | Total cholesterol (mg/dl)
  [b2] | Low-density lipoprotein (mmol/l)
  [b3] | Total carotenoids (mg/dl)
  [b4] | Other units (specify):
2. | Name of test or brief description of method used to measure outcome:
3. | Validity of biochemical procedure
  a. | Did the study "self-validate" the biochemical procedure? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the procedure was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
4. | a. Relationship to fruit and vegetable outcome
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)
  b. | Relationship to dietary fat outcome:
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)
  c. | Relationship to behavioral mediator:
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)

Findings for Biochemical Indicator -- Measure 1
5. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
6. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
7. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
8. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
37b. | Biochemical Indicators of Dietary Intake -- Measure 2 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | Total cholesterol (mg/dl)
  [b2] | Low-density lipoprotein (mmol/l)
  [b3] | Total carotenoids (µg/dl)
  [b4] | Other units (specify):
2. | Name of test or brief description of method used to measure outcome:
3. | Validity of biochemical procedure
  a. | Did the study "self-validate" the biochemical procedure? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the procedure was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
4. | a. Relationship to fruit and vegetable outcome
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)
  b. | Relationship to dietary fat outcome:
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)
  c. | Relationship to behavioral mediator:
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)

Findings for Biochemical Indicator -- Measure 2
5. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
6. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
7. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
8. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
37c. | Biochemical Indicators of Dietary Intake -- Measure 3 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | Total cholesterol (mg/dl)
  [b2] | Low-density lipoprotein (mmol/l)
  [b3] | Total carotenoids (µg/dl)
  [b4] | Other units (specify):
2. | Name of test or brief description of method used to measure outcome:
3. | Validity of biochemical procedure
  a. | Did the study "self-validate" the biochemical procedure? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the procedure was
  | established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
4. | a. Relationship to fruit and vegetable outcome
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)
  b. | Relationship to dietary fat outcome:
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)
  c. | Relationship to behavioral mediator:
  | (Specify outcome):
  | 0.__ __ (correlation coefficient)

Findings for Biochemical Indicator -- Measure 3
5. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
6. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
7. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
8. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes
38a. | Other Dietary Outcome -- Measure 1 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | Dietary quality score (describe in detail all components used to calculate score and general procedures for scoring):
  [b2] | Dietary fiber - grams per day
  [b3] | Dietary fiber - servings of whole wheat per day
  [b4] | Dietary fiber - servings of high-fiber cereal per day
  [b5] | Dietary fiber - other units (briefly describe):
  [b6] | Dietary calcium - grams per day
  [b7] | Dietary calcium - other units (briefly describe):
  [b8] | Other dietary outcome (specify units):
2. | Name of instrument used to collect dietary information:
3. | Type of instrument (check all that apply):
  [a] | Food frequency/checklist (list number of items included): _____ items
  [b] | 24-hour recall (list number of days used): __ __ days
  [c] | Food record (list number of days used): __ __ days
  [d] | History
  [e] | Food behavior scale/items (e.g., low-fat milk, taking skin off chicken)
  [f] | Other (specify:)
  [g] | Not reported
4. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
5. | Reliability (or internal consistency) of dietary instrument
  a. | Did the study provide information about the reliability of the dietary instrument? [1] yes [0] no
  | If "yes," fill in reliability information below:
  | 0.__ __ (circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):

Findings for Other Dietary Outcome -- Measure 1
6. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
7. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
8. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
9. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
38b. | Other Dietary Outcome -- Measure 2 | 0 Not Reported 1 Reported (Briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | Dietary quality score (describe in detail all components used to calculate score and general procedures for scoring):
  [b2] | Dietary fiber - grams per day
  [b3] | Dietary fiber - servings of whole wheat per day
  [b4] | Dietary fiber - servings of high-fiber cereal per day
  [b5] | Dietary fiber - other units (briefly describe):
  [b6] | Dietary calcium - grams per day
  [b7] | Dietary calcium - other units (briefly describe):
  [b8] | Other dietary outcome (specify units):
Note: Complete items 2-5 only if different from Other Dietary Outcome -- Measure 1
2. | Name of instrument used to collect dietary information:
3. | Type of instrument (check all that apply):
  [a] | Food frequency/checklist (list number of items included): _____ items
  [b] | 24-hour recall (list number of days used): __ __ days
  [c] | Food record (list number of days used): __ __ days
  [d] | History
  [e] | Food behavior scale/items (e.g., low-fat milk, taking skin off chicken)
  [f] | Other (specify:)
  [g] | Not reported
4. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was established? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
5. | Reliability (or internal consistency) of dietary instrument
  a. | Did the study provide information about the reliability of the dietary instrument? [1] yes [0] no
  | If "yes,"fill in reliability information below:
  | 0.__ __ (circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):

Findings for Other Dietary Outcome -- Measure 2
6. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
7. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
8. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1 _____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported) _____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
9. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes:

F. Study Outcomes (continued)
38c. | Other Dietary Outcome -- Measure 3 | 0 Not Reported 1 Reported (briefly list outcome):
1. | Units for outcome (circle one, and indicate if the variable was logged/back-transformed):
  [b1] | Dietary quality score (describe in detail all components used to calculate score and general procedures for scoring):
  [b2] | Dietary fiber - grams per day
  [b3] | Dietary fiber - servings of whole wheat per day
  [b4] | Dietary fiber - servings of high-fiber cereal per day
  [b5] | Dietary fiber - other units (briefly describe):
  [b6] | Dietary calcium - grams per day
  [b7] | Dietary calcium - other units (briefly describe):
  [b8] | Other dietary outcome (specify units):
Note: Complete items 2-5 only if different from Other Dietary Outcome -- Measure 1
2. | Name of instrument used to collect dietary information:
3. | Type of instrument (check all that apply):
  [a] | Food frequency/checklist (list number of items included): _____ items
  [b] | 24-hour recall (list number of days used): __ __ days
  [c] | Food record (list number of days used): __ __ days
  [d] | History
  [e] | Food behavior scale/items (e.g., low-fat milk, taking skin off chicken)
  [f] | Other (specify:)
  [g] | Not reported
4. | Validity of dietary instrument
  a. | Did the study "self-validate" the dietary instrument? [1] yes [0] no
  | If "yes," specify measure used as criterion/comparison measure:
  | If "yes," fill in validity information below:
  | 0.__ __ (circle one): [a] correlation coefficient [b] other (specify):
  b. | Did the study cite a validation study in which the validity of the dietary instrument was etablished? [1] yes [0] no
  | If "yes," write the citation provided by the authors:
5. | Reliability (or internal consistency) of dietary instrument:
  a. | Did the study provide information about the reliability of the dietary instrument?
  | [1] yes [0] no
  | If "yes," fill in reliability information below:
  | 0.__ __ (circle one): [a] Cronbach's alpha [b] test-retest [c] other (specify):

Findings for Other Dietary Outcome -- Measure 3
6. | Are the statistical results presented for: | Yes
| a. The entire sample (or intervention vs. control) | 1
| b. A subsample (e.g., males and females separately) | 1
| If results are presented for a subsample, briefly describe, and obtain additional forms to report the results for another subgroup if necessary:
7. Briefly describe the statistical procedure used to determine whether the intervention had a significant effect on dietary intake (e.g., compared means using t-tests, compared proportions using chi-square, used a "treatment" by "time" interaction term in a regression model)
8. Statistics (see guidelines for instruction)

| Intervention Group(s) | | | Control Group
Baseline differences b/w groups: | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at baseline. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., s.e, %) and the numerical value. If you present means, include s.d. or s.e. (specify which). If you present odds ratios, include 95% CI.
Differences at follow-up 1_____weeks after intervention^1^ | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 1. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
Differences at follow-up 2 (if reported)_____weeks after intervention | n | statistic | p | n | statistic | p
In the boxes to the right, report any statistics used to determine whether the intervention group(s) and control group differed in the measure at follow-up 2. Provide the sample size, statistic reported, and p value. Write the name of the statistic (i.e., mean, s.d., OR) and the numerical value.
9. Other findings (see guidelines) (e.g., a third follow-up period was considered) or notes: