# Appendix A. Acknowledgments

This study was supported by Contract No. 290-97-0011 from the Agency for Healthcare Research and Quality (AHRQ, formerly Agency for Health Care Policy and Research). This evidence report was produced in response to an RFA from AHCPR (now AHRQ) made available for bidding to all EPCs: RFP AHCPR-97-0001. We acknowledge the assistance of Jacqueline Besteman, JD, MA, the AHRQ Task Order Officer for the Evidence-based Practice Center Program, and Kate Rickard, MPA, the AHRQ Task Order Officer for this project.

The Technical Expert Advisory Group (TEAG) played an integral and active role in shaping and producing this evidence report.

In addition, the RTI/UNC EPC wishes to thank its Scientific Advisers, Lenore Arab, PhD, Marci Campbell, PhD, RD, and Thomas Keyserling, MD, MPH, for providing their expertise throughout the project.

The investigators appreciate the time and assistance of the clinical and methods data abstractors. The clinical data abstractors were Semra Aytur, MPH, Kerry-Ann daCosta, PhD, Denise D. Dickinson, MPH, Alyssa Ghiradelli, MPH, RD, Christine S. Hardy, RD, and Hugh C. Law, RD. The methods abstractor team were Tracy L. Bouchard-Cyr, MSPH, Nancy A. Davis, MSHE, MPH, Ho-Jui Tung, MPH, Kimberly Truesdale, MSPH, and Carole Toselli, MD. The expertise of Lynn Whitener, DrPH, MSLS, and Susan Tolleson-Rinehart, PhD, as well as the administrative assistance of Donna Curasi and Joan Kavanaugh, were also fundamental to the data collection and dissemination phases of the project.

We thank the following individuals from the University of North Carolina at Chapel Hill: Gordon DeFriese, PhD, Co-Director of the RTI-UNC Evidence-based Practice Center, Timothy S. Carey, MD, MPH, Scientific Adviser to the RTI-UNC Evidence-based Practice Center, and the RTI/UNC EPC Executive Scientists, Steven Zeisel, MD, PhD and Michael S. O'Malley, PhD.

We thank Russell Glasgow, PhD, and Ralph Coates, PhD, for providing additional data needed for the meta-analysis; in turn, we appreciate the time and effort that Norma Gavin, PhD, Christopher Wiesen, PhD, and Victor Hasselblad, PhD, spent designing the meta-analysis.

Finally, we are grateful for the guidance and assistance we received from Linda Lux, MPA, Nancy Berkman, PhD, Anjolie Idicula, BA, and Suzanne L. West, PhD, in preparing this report, Linda Fonville for her outstanding wordprocessing support, and Nicole Walker, Richard Strowd, JD, and Tim Weinzapfel, CACM, for their exceptional contracting support.

## Technical Expert Advisory Group

We gratefully acknowledge the substantial involvement of and assistance from the technical expert advisory group (TEAG). TEAG members are listed at the end of this Appendix. The TEAG served many roles in this project. Its reason for existence was, in essence, to (1) advance AHRQ's broader goals of forging and sustaining partnerships in the health sector as well as the consumer and private sectors, and (2) meet the needs of an expansive array of potential customers and users of its products. In sum, the TEAG was both a substantive resource and a "sounding board" throughout the study. It was also the body from which expertise was formally sought at several junctures.

The TEAG was composed of experts in a field relating to nutrition or behavior with respect to cancer risk. They included (1) technical/clinical experts, (2) an educated representative of the population at large, and (3) a technical expert from an organization whose mission concerns the interest and perspectives of patients and consumers. In sum, the eight members of the TEAG were one clinician, six technical experts, one representative of an organizational perspective, and one representative of potential user groups. The final decision about TEAG membership was based on candidates' availability for scheduled conference calls, availability to provide input, willingness to review materials, and ability to give advice and assistance within a short turnaround time. All members had to be approved by the AHRQ Task Order Officer.

The RTI-UNC EPC team solicited the views of TEAG members from the beginning of the project. Among other issues, TEAG members provided insights into and reactions to key clinical questions, input to the literature review process by ensuring that we included all known published research meeting our inclusion criteria, review of our data abstraction forms, and comments on our approach to the meta-analysis.

In keeping with AHRQ's standards for employing a multidisciplinary approach to the development of evidence reports, we called on our TEAG at key points during this task. First, the group was asked to comment on the literature synthesis and to give us feedback on our overall plans at that stage of the analysis, which included approaches to developing evidence tables. Second, the TEAG was consulted on the feasibility of performing a meta-analysis on fruit and vegetable literature. Last, the TEAG provided input on analysis strategies as well as input on the dietary fat meta-analysis.

### Technical Expert Advisory Group (TEAG)

- Cheryl L. Achterberg, PhD
- Dean, The Schreyer Honors College 214 Willard Building The Pennsylvania State University University Park, PA 16802 (814) 863-2635 fax (814) 863-8688 agy@psu.edu

- Karen Glanz, PhD, MPH
- Professor, Cancer Prevention and Control Program University of Hawaii Cancer Research Center of Hawaii 1236 Lauhala Street, Suite 406 Honolulu, HI 96813 (808) 586-3076 fax (808) 586-3077 kglanz@hawaii.edu

- Tom Baranowski, PhD
- Professor of Behavioral Nutrition Children's Nutrition Research Center Department of Pediatrics Baylor College of Medicine 1100 Bates Houston, TX 77030 (713) 798-6636 tbaranow@bcm.tmc.edu

- Susan J. Curry, PhD
- Group Health Cooperative of Puget Sound Director, Center for Health Studies 1730 Minor Avenue, Suite 1600 Seattle, WA 98101 (206) 287-2873 fax (206) 287-2871 Curry.s@ghc.org

- Russell E. Glasgow, PhD
- AMC Cancer Research Center 11716 98th Place SW Vashon, WA 98070 (206) 567-5915 (303) 239-3341 fax (303) 239-3500 glasgowr@amc.org

- Shiriki Kumanyika, PhD, MPH
- Associate Dean for Health Promotion and Disease Prevention Professor of Epidemiology University of Pennsylvania School of Medicine Center for Clinical Epidemiology and Biostatistics 8th floor Blockley Hall 423 Guardian Drive Philadelphia, PA 19104-6021 (215) 898-2629 fax (215) 573-5315 skumanyi@cceb.med.upenn.edu

- Rev. Joseph C. Paige, EdM, MDiv, EdD
- Professor, Interim Provost Shaw Divinity School PO Box 27924 Raleigh, NC 27611 (919) 833-4809

## Peer Reviewers

An important first step in the identification of potential peer reviewers was to determine the appropriate constituencies from which our reviewers should be approached. The categories that were determined and the number of reviewers who accepted our invitation to serve as peer reviewers for this report are (1) scientific experts (including three to four peer reviewers) and (2) experts from health-related organizations or societies (including six peer reviewers).

We believe that these two categories represent the full range of health care experts, users, and patient groups that should be involved in reviewing this evidence report on the efficacy of behavioral dietary intervention. The specific peer reviewers are listed at the end of this appendix.

Our peer reviewer panel also includes the eight members of the TEAG because they played a major role throughout the project in conceptualizing the work and reviewing materials; moreover, because they are active professionals in the field, the RTI/UNC EPC believed that their comments at this stage would be very valuable. The peer reviewers who were not members of the TEAG were identified by issuing an invitation to the organization's executive officer/director (e.g., president, CEO) or to a public sector agency head asking them to nominate a peer reviewer and by soliciting nominations from the TEAG. A preliminary (and longer) list of organizations, agencies, or individuals was submitted to the AHRQ Task Order Officer for this project for review, comment, and approval. We then contacted all potential peer reviewers to determine their willingness to serve as peer reviewers, alerting them to the fact that this service would require them to prepare formal written reviews according to the checklist developed for this evidence report. Their comments and suggestions formed the basis of our revisions to the evidence report.

### Peer Reviewer List

#### Individuals

- Sharon K. Davis, MEd, MPA, PhD
- Associate Professor and Director Morehouse School of Medicine Ethnicity, Policy, and Social Epidemiology Research Program MRC-248 Atlanta, GA 30310-1495 (404) 752-1627 fax (404) 752-1154 skdavis@msm.edu

- C. Tracey Orleans, PhD
- Senior Scientist Robert Wood Johnson Foundation College Road East PO Box 2316 Princeton, NJ 08543 (609) 243-5962 fax (609) 987-8746 cto@rwjf.org

- Kathleen Fairfield, MD, MS
- Instructor in Medicine Harvard Medical School Lilly 330, Division of General Medicine Beth Israel Deaconess Medical Center 330 Brookline Avenue Boston, MA 02215 (617) 667-3454 fax (617) 667-2751 kfairfie@caregroup.harvard.edu

#### Organizations

- Colleen Doyle, MS, RD
- Director, Nutrition and Physical Activity American Cancer Society 1599 Clifton Road, NE Atlanta, GA 30329 (404) 329-7575 fax (404) 248-1780 Cdoyle@Cancer.org

- Leslie Lytle, PhD, RD
- American Dietetic Association Associate Professor of Epidemiology University of Minnesota Epidemiology, WBOB 1300 South 2nd Street Minneapolis, MN 55454 (612) 624-1818 fax (612) 624-0315 lalytle@tc.umn.edu

- Cheryl Rock, PhD
- Society of Behavioral Medicine Associate Professor, Department of Family and Preventive Medicine Cancer Prevention and Control Program University of California San Diego 9500 Gilman Drive, Department 0901 La Jolla, CA 92093-0901 (858) 822-1126 fax (858) 822-1497 clrock@ucsd.edu

- Arthur Hadley, MD
- American College of Preventive Medicine 11777 Katy Freeway Houston, TX 77079 (281) 597-1010 fax (281) 597-0015 ahadley@wt.net