# Evidence Tables

Evidence Table 1. Studies of diagnosis and management for store-and-forward telemedicine in pediatric, obstetric and clinician-indirect home telemedicine

| Quality Score | Clinical Domain | Sample | Intervention | Effects - Diagnosis | Effects - Management
Patterson, 1998^8^ | II-C | Dental screening | 27 patients | Diagnostic and management agreement of dentists in oral screening | Kappa for agreement on decay was 0.50-0.58 | Kappa for agreement on extraction and filling was 0.93-1.0
Schwartz, 2000^9^ | III-B | Opththalmology | 19 eyes in 10 patients | Diagnostic and management agreement in patients who had retinopathy of prematurity | Agreement was 89-95% for diagnosis | Agreement in management plans was 42%
Yamamoto, 1996^10^ | III-B | Neonatology | 31 patients | Accuracy of CXR interpretation between neonatologists using telemedicine and general pediatrician and agreement of level of care assignment between neonatologists and general pediatrician | Neonatologists identified 91-98% of findings vs. 82% for general pediatrician; neonatologists assigned level of care 73% of time with written CXR report and 67% of time with image | Not assessed

Evidence Table 2. Studies of access for store-and-forward telemedicine in pediatric, obstetric and clinician-indirect home telemedicine^1^

Source | Domain | Intervention | Control | Sample | Results | Comments | Study Class
Patterson, 1998^8^ | Pediatrics, Dentistry | Telehealth communication technology & intraoral camera for visual dental screening at school by dentists | None, except former mode of practice in general (visual inspection by dental hygenists or assistants) | n = 135 children in school | Improved access to dental expertise for screening = 100% | | III - B

1 Study class definition in this evidence table is relevant to the key question of whether telehealth resulted in comparable or improved access.

Evidence Table 3. Studies of access for self-monitoring/testing in pediatric, obstetric and clinician-indirect home telemedicine

Source | Domain | Intervention | Control | Sample | Results | Comments | Study Class
Cartwright, 1992^16^ | Obstetrics | BP monitoring telemetrically from home (10 measures/10 min) to a portable computer carried by provider that alerts by individualized level | Randomized control trial; control = BP monitoring in hospital every 4 hrs | n = 99 pregnant hypertensive pts referred by providers over 1 yr, E = 36, C = 31 | Improved access = 100% for E pts | Of 100 in sampling pool, 5 declined; 4 withdrew; 24 did not complete data or had clinical problems so were excluded; no differences in sample and drop-outs in 6 characteristics; no differences in study groups in 14 characteristics | I - B
Dawson, 1999^17^ | Obstetrics, Home care | Home fetal & maternal monitoring via phone modem + home visits | Randomized to home or clinic care | E = 43, C = 38, high risk, MD-approved pts without complications requiring hospitalization | Improved access (greater number of mean home care visits) for mod hi risk pts: E = 3.7, C = 1.4 (p < .005); fewer clinic visits (2.4 vs 3.2), hospital days (3.5 vs 5.13) & less time lost from work (.05 vs 1.14 hrs, p = .11) | No declines, no drop-outs; group differences in access to phones & satisfaction with living place favored E group (though p values not reported); authors acknowledged insufficient statistical power because neither group was "pure" on key characteristics | I - A
di Biase, 1997^14^ | Obstetrics | Electronic glucometer (DIANET) for data transmittal via telephone modem + insulin adjustment software available to clinic staff | Randomized to electronic self-monitoring or non-electronic self-monitoring | n = 20 consecutively selected clinic pts, E = 10, C = 10 | Improved access to insulin adjustment advice, E > C (E = 24 hr if desired, C = home visits during business hrs); | C had more frequent in-person home visits due to closer distance (C = weekly, E = every 15-30 days), (specific frequencies not reported, distances not reported), E > C in access satisfaction; small sample | II - B
Brennan, 1995^20^ | Home care | Computer network via WYSE terminal for information, communication & decision support | Randomized to intervention or control (no TMED at home) | n = 98 recruited caregivers of persons with Alzheimer's Disease, E = 47, C = 51 | Improved access = 100% E, to nurse & support services (information, social support, decision analysis) - average 83 encounters/12 mos, all hrs, day & night ; access not impaired by lack of computer skills | 3 assigned to E group unable to participate (2 had technical installation problems, 1 became ill); drop-outs: E = 1, C = 2; no measures of clinic or phone access to nurse for support or decision making were made in the comparison group | II - A
Flatley-Brennan, 1998^19^ | Home care | Computer network via WYSE terminal for information, communication & decision support | Randomized to intervention or control (no TMED at home) | n = 57 of 61 recruited adults with AIDs, E = 31, C = 26 | Improved access = 100% E, to nurse & support services (information, social support, decision analysis) - average 297encounters/6 mos, all hrs, day & night ; access not impaired by lack of computer skills | 4 declined; 6 drop-outs; no group differences; discrepancy in number of total encounters with the system (abstract states 192/pt; report states 297/pt; total is consistently reported as 8449, which if divided by 31 subjects is 272; no measures of clinic or phone access to nurse for support or decision making were made in the comparison group | II - A
Frost, 2000^15^ | Obstetrics | Electronic glucometer (CareLink) for data transmittal via telephone modem + insulin adjustment software available to clinic staff | Non-electronic data reports during clinic visits | n = 21 Type 1 diabetes pts on intense insulin therapy, matched for diabetic conditions, E = 11, C = 10 | Improved access E > C, E = mean 3.3 wks between clinic visits, C = mean 2.9 wks between clinic visits | Authors noted that electronic data monitoring offered greater access to timely care for those who have trouble accessing clinic care, but did not measure distances nor visit frequencies | II - B
Gray, 2000^13^ | Pediatrics | Videoconferencing & Internet communication (Baby CareLink) between home & NICU | Randomized to intervention or control (no TMED at home) | n = 56 families of very low birth wt infants with ISDN access at home, E = 26, C = 30 | Improved access = 100% E | Of families of 176 VLBW infants, 88 were eligible, 9 declined, 4 unavailable to consent, some multiple births/family; equipment & service provided by government - so external validity limited to those with similar support; access from home by telephone may have been comparable | II - B
Gustafson, 1999^21^ | Home care | In-home computer access | Randomized to intervention or control (no TMED at home) | n = 193 men with AIDs: E = 96, C = 87 | Improved access = 100% E | Of 219 recruited, 15 excluded by criteria; drop-outs: E = 11, C = 10 | I - A
Marrero, 1995^12^ | Pediatrics, Home care | Home self-monitoring & q 2 wk transmittal of blood glucose data via modem + NP review & consultation for adjustment | Randomized to E, C (routine care with MD providing insulin adjustment consultation q 3 mos) | n = 106 pediatric diabetic clinic pts < 5 yrs on insulin > 6 mos, with a home phone, E = 52, C = 54 | Improved access = 100% E to an NP; equivalent access (E = C) of electronic vs verbal data reporting from home | Nurses initiated frequent contact after receiving q 2wk glucometer data, which influenced access, in contrast with clinic system of q 3 mos data transmittal | I - A
Miyasaka, 1997^11^ | Pediatrics | A near-television quality home digital videophone system (ISDN 64, 320 x 200 resolutions, 10-12 fps, for home ventilatory care | Pre-post comparison, 7 pts were own controls, receiving ventilatory home care 6 mos prior to the intervention | n = 10, group I = 3, aged 10 - 20 mos, group II = 7, aged 3 - 24 | Group I access to providers increased from 11 to 58 calls (p < .004), access to home instead of hospital from 24 to 5 hospital visits (80% decrease, p < .01); hospital decreased from 22 to 10 days & hospital admits decreased from 4 to 2 (not significant); Group II access to providers = 45 calls, 1 hospital visit, 0 hospital days & admits (77% reduced hospital visits & admissions) | Eligibility included living within ISDN service area; 20 post-system calls were social calls, suggesting the videophone may have been perceived as a novelty; time saved by physicians (51.2 hrs) increased access for other pts; families saved 95 hrs of travel with the system; pts began to access each other to increase their social support; no control for seasonal effects, which varied by pt | II - B
Torok, 1999^18^ | Obstetrics | Computer-aided monitoring with portable uterine contraction monitor; pt monitors contraction activity for 4 days, BID, for minimum 2 hrs; data transmitted to MD | Randomized to intervention or control | n = 263 of 748 multi-center pts in all risk categories who completed all monitoring & treatment requirements | Improved access = 100% (home care vs clinic care? for uterine monitoring) pre-delivery; reduced preterm-birth rate by 50%, increasing access to home care for newborns | Details not reported, e.g. control group description, group sizes, group characteristics or drop-out reasons | II - B

Evidence Table 4. Studies of outcomes for self-monitoring/testing in pediatric, obstetric and clinician-indirect home telemedicine

| Quality Score | Clinical Domain | Sample | Intervention | Effects
di Biase, 1997^14^ | II-B | Gestational Diabetes | 20 patients | Home blood sugar monitoring (RCT) in gestational diabetes | Computer group had HgbA1c drop from 6.4% to 5.0%; control group from 7.1% to 5.7%
Cartwright, 1992^16^ | I-B | Hypertension | 99 patients | Anxiety, blood pressure readings, and gestational age at delivery in home vs. hospital-monitored women | Comparable levels of anxiety, mean blood pressure, and gestational age of delivery
Flatley-Brennan, 1998^19^ | I-B | AIDS | 57 patients | Social isolation and decision-making skill for home computer network (RCT) | Reduced social isolation when controlled for depression and improved confidence in decision-making with increased use
Brennan, 1995^20^ | I-B | Alzheimer's | 102 caregivers | Social isolation and decision-making skill for home computer network (RCT) | Improved decision-making confidence but no improvement in decision-making skill or social isolation
Miyasaka, 1997^11^ | III-B | Pulmonary | 10 patients | Amount of unscheduled care before and after installtion of videophone access to physician | Reduction in number of house calls (5 vs. 0), unscheduled hospital visits (24 vs. 5), and hospital admission days (22 vs. 10)
Frost, 2000^15^ | II-B | Gestational Diabetes | 21 patients | Home blood sugar monitoring | Computer group had HgbA1c drop from 6.1% to 5.4%; control group from 6.2% to 5.7%
Marrero, 1995^12^ | I-B | Diabetes | 106 patients | Home blood sugar monitoring (RCT) | Computer group had HgbA1c rise from 9.4% to 10.0%; control group from 9.9% to 10.3%; no difference in ER visits, psychological status, or family functioning
Gustafson, 1999^21^ | I-A | AIDS | 183 patients | Quality of life and hospitalizations | Improvement in active life, negative emotions, cognitive functions, social support, and participation in health care; fewer hospitalizations
Gray, 2000^13^ | II-B | Neonatology | 56 patients | Quality of care and hospitalization | Trend towards earlier discharge from hospital

Evidence Table 5. Studies of patient satisfaction for self-monitoring/testing in pediatric, obstetric and clinician-indirect home telemedicine

Source | Setting | Population | Study Design | | | | | Results | Comments
| | | Study class | Sample | Site(s) | Control | Instruments
Gray 2000^13^ | Neonatal ICU and home - equipped with Baby CareLink via Internet connection and video conferencing using ISDN | Very Low Birth Weight (VLBW) Infants and families | I A | Infants admitted to ICU during study period who met inclusion criteria randomly assigned to study (N=26) or Control (N=30). 61% response rate = total of 31 surveys returned | 1 | Randomly assigned (N=30) | Picker Institute Neonatal Intensive Care Unit Family Satisfaction Survey | Study group scored significantly (p<.05) higher in quality of care and environment/visitation policy scales. "Trend" higher in 4/6 other measures but not significant. | Web/videoconferencing system to facilitate communication and provide education and emotional support to families of VLBW infants during and after NICU stay.

Evidence Table 6. Studies of diagnosis and management for clinician-interactive telemedicine in pediatric, obstetric and clinician-indirect home telemedicine

| Quality Score | Clinical Domain | Sample | Intervention | Effects - Diagnosis | Effects - Management
Kofos, 1998^22^ | II-B | Emergency medicine | 15 patients | Agreement between in-person emergency room physician (gold standard) and pediatric critical care specialist via telemedicine for physical exam findings | Sensitivity of abnormal findings was 87.5% and specificity was 93.0% | Not assessed
Belmont, 1995^24^ | I-B | Stethoscopy | 116 patients | Diagnostic agreement of cardiologists in acoustic, electronic, and tele-electronic stethoscopy | Kappa for agreement on acoustic vs. electronic was 0.65 and for acoustic vs. tele-electronic was 0.64 | Sensitivity and specificity of need for follow-up consult or echo were 88% and 97% respectively
Elford, 2000^23^ | II-B | Child psychiatry | 23 patients | Diagnostic and management plan agreement as determined by independent psychiatrist | Diagnostic agreement was 96% | Agreement with management plan was 96%
Casey, 1996^25^ | II-B | Cardiology | 9 patients | Agreement of exam guided by cardiologist vs. in-person cardiologist | 88% of diagnoses correct | Not assessed

Evidence Table 7. Studies of access for clinician-interactive telemedicine in pediatric, obstetric and clinician-indirect home telemedicine

Source | Domain | Intervention | Control | Sample | Results | Comments | Study Class^1^
Casey, 1996^25^ | Pediatrics, Cardiology | TMED videoconf & ISDN transmitted echocardiogram for consultation | None, except former mode of practice in regional center in general | N = 10 infants needing urgent echo according to pediatrician for congenital heart disease | Improved access = 80% (avoided transfer to regional center in 8 of 9 cases); equivalent access = 20% (1 case + 1 non-case for better imaging) | Pilot test | III-B
Casey, 1998^26^ | Pediatrics, Cardiology | TMED videoconf & ISDN transmitted echocardiogram for consultation | None, except former mode of practice in regional center in general | n = 61 infants aged 1-42 days with congenital heart disease | Improved access = 77% (26 = minor CHD, 21 = no CHD); no change in access for 23% (12 = major CHD transported to regional center for urgent care, 2 = minor CHD) | Access for urgent care of 12 pts with major CHD was quicker than if remote consultation had not occurred, but times not reported | III-B
Chan, 2000^35^ | Obstetrics | Ultrasound consultation from OB-GYNs by videoconference | None, except former mode of practice in regional center in general | n = 24 consultations in low- & high-risk pts | Improved access = 100% (nearer home by 1500 km) for screening; 12% (3) for delivery (e.g. no transfer required); no emergency access needed | Question of emergency care access from local clinic vs regional center is unanswered | III-B
Chi, 1999^36^ | Obstetrics, Pediatrics | Video consultation from remote emergency dept | In-person regional center consults in prior year | 275, including 20 OB and 3 Pediatrics pts, seen for consultations | Improved access = 31% (fewer transfers from remote to metropolitan hospital) | Comparison number of transfers appear to be an error stating comparison yr as 1998 instead of 1995. | II-B
Finley, 1997^27^ | Pediatrics, Cardiology | Video for echocardiography consultation | None, except former mode of practice with travel to regional center in general | n = 135 transmissions | Improved access = 28% (31 of 112 cases that got local care after consultation, but were considered emergencies) | No discussion re how judgements of emergency status determined in subjects | III-B
Holtan, 1998^32^ | Pediatrics | Otolaryngology consultation between GP and specialist | None, except former mode of practice with consultation in regional center | n = 17 6 parents, 11 adult pts | Improved access = 100% (same community as home) + perceived:; 1. quicker access to MD;; 2. greater access to information than with in-person consultant | Of 35 eligible, 15 refused & 3 excluded for practical & financial reasons; data collected by unstructured interviews | III-B
Karp, 2000^33^ | Pediatrics | Consultation via T-1 network from regional center to rural clinic | None, except former mode of practice with travel to regional center in general | n = 201 children aged .5 to 20 yrs with genetic & neurologic disorders | Improved access = 100% (care closer to home) with 333 consultations; reduced travel = from average 354 to 265 miles (89 miles closer)/pt | | III-B
Massman, 1999^34^ | Pediatric (partial sample) | Efficiency & effectiveness of burn consultations via TMED | None, except former mode of practice with travel to regional center in general | n = 40 pts seen for 87 follow-up visits at 15 TMED sites in 6 states, aged 1-71 | Improved access = 100%; pt travel reduced 572 mi/pt or 49,804 miles total; limited access = 100% delays (exam prep limited to 1 room, camera adjustments to view skin, technical problems with cut-offs & difficulty switching from site to site) | | III-B
Rendina, 1997^29^ Rendina, 1998^28^ | Pediatrics, Cardiology | System for rapid interpretation of neonatal echocardiograms by consultation | Admits to NICU in prior year, same period, not using system | E = 48 infants, C = 39 infants | Improved access = 100% E + reduced time from "several days to a few hrs" | Detailed results not provided | II-B
Sable, 1999^30^ | Pediatrics, Cardiology | Real-time echocardiography consultation from pediatric cardiologists for neonatologists in under-served areas via desktop videoconferencing computers (Video Systems Inc) using 3 ISDN lines; 23-30 fps | None, except former mode of practice in general | n = 60 echograms in 48 neonates with congenital heart disease, PDA & hemodynamic instability | 100% improved local access to diagnostic quality for screening; 50% improved access for treatment (5 pts transported to regional center, 5 pts not transported though expected to need it); access to insurance funding averaged 55-60% | Videoconference access time per consultation was given, but no comparison time | III-B
Whitten, 2000^31^ | Pediatrics | Interactive video-links from schools to doctors-teachers', nurses' & administrators' perceptions | None, except former mode of practice in general | Phase I, nearly 200 video consultations, Phase II, 371 consultations | 100% screening access to consultation from inner city schools to university medical center | Details not reported relative to comparison conditions relevant to access | III-B

1 Study class definition in this evidence table is relevant to the key question of whether telehealth resulted in comparable or improved access.

Evidence Table 8. Studies of outcomes for clinician-interactive home telemedicine in pediatric, obstetric and clinician-indirect home telemedicine

| Quality Score | Clinical Domain | Sample | Intervention | Effects
Rendina,1998^28^ Rendina, 1997^29^ | II-B | Neonatology | 314 patients | Length of stay in NICU for telemedicine vs. no telemedicine | LOS decreased significantly related to birth weight

Evidence Table 9. Studies of satisfaction for clinician-interactive services in pediatric, obstetric, and patient-indirect telemedicine

Patient Satisfaction
Source | Setting | Population | Study Design | | | | | Results | Comments
| | | Study class | Sample | Site(s) | Control | Instruments
Elford, 2000^23^ | Outpatient child psychiatry clinic using televideo conferencing over ISDN lines | Children aged 4-16 and parents | II B Cross over | Convenience sample 23 patients | 1 | Patients/parents served as own controls | Unvalidated questionnaires | No significant difference noted between face to face sessions and video-conferencing; 91% parents would prefer telemedicine to long travel | Small sample size; Two exams performed in two days - possible learning effect
Karp, 2000^33^ | Outpatient pediatric subspecialty clinics using T1 lines to provide interactive audio, video, and diagnostic instruments | Children with special needs and their caregivers | III A | 127/141 Consecutive referrals - 90% response rate | 1 | None | Client Satisfaction Survey (validated) | Likert scores 3.7-3.8/4.0 (highest) for several aspects of patient satisfaction | Telemedicine visits were used to augment face-to-face visits at remote clinics by the same subspecialty staff.
Elford, 2000^23^ | Outpatient child psychiatry clinic using televideo conferencing over ISDN lines | Child psychiatrists | II C Cross over | Convenience sample 5 child psychiatrists | 1 | Subjects served as own controls | Unvalidated questionnaires | Significant preference for face to face interviews; Video viewed as "acceptable" alternative; did not hinder history | Small sample size; Difference between psychiatrists may have influenced results
Karp, 2000^33^ | Outpatient pediatric subspecialty clinics using T1 lines to provide interactive audio, video, and diagnostic instruments | Pediatric subspecialty faculty | III B | All 60 faculty surveyed - 92% response rate (n=56) | 1 | None | Unvalidated survey | 70% reported positive attitude toward telemedicine; 44% felt it was cost-effective, 48% time effective; increase experience correlated with more positive responses (r=.3); (p<.05) | Reference made to faculty attitudes at onset and after 1 year. Faculty were surveyed at 9 months after start of project of the 18 month reporting period. Specific faculty experience with telemedicine was variable.

Evidence Table 10. Studies of cost for all study areas

Part 1 - Study overview
Source | Technology | Specialty | Quality Score | Country | Study Type | Perspective | Comparisons | Primary Outcome
Rendina et al. 1997^29^ and 1998^28^ | Clinician Interactive | pediatric cardiology | <2 of 5 | US (NC) | cost study | hospital system | pre- and post-telemedicine implementation | ICU length of stay, transfer rates, mortality rates
Finley et al., 1997^27^ | Clinician Interactive | pediatric cardiology | <2 of 5 | Canada | case series | health care system | description of case series | diagnostic accuracy
Sable,1999^30^ | Clinician Interactive | pediatric cardiology | <2 of 6 | US (LA) | cost analysis | health care system | evaluation by transmitted echocardiograms versus helicopter transport and cost comparisons for transported patients | telemedicine cost versus transport cost and costs of care for transported patients

Evidence Table 10. Studies of cost for all study areas

Part 2 - Cost analysis details
Source | Cost Data Sources | Cost Accounting Sources Included | Cost Unit | Discount Rate (base case) | Results | Sensitivity Analyses
Rendina et al. 1997^29^ and 1998^28^ | Actual local costs | telemedicine application only | US $ | NA | shorter length of stay (5.4 days, p=0.2), potential for large cost savings | none
Finley et al., 1997^27^ | actual local costs | telemedicine application only | Can $ | NA | transport costs saved more than offset cost of telemedicine application | none
Sable,1999^30^ | actual costs (charges?) | telemedicine equipment only | US $ | NA | reduced helicopter transport will offset telemedicine equipment costs; higher costs for care of transported patients with telemedicine than usual care | none

Evidence Table 10. Studies of cost for all study areas

Part 3 - Quality criteria
Source | Perspective Stated | Prog Benefit Described | Intervention Costs Included | Morbidity/SE Costs Included | Averted Costs Included | Induced Costs Included | Costs/Benefits Discounted | Sensitivity Analyses | C/E Ratio Estimated
Rendina et al. 1997^29^ and 1998^28^ | Y (hospital) | Y (length of stay) | Y | N | N | N | NA | N | N
Finley et al., 1997^27^ | N (health care system) | Y (transport) | Y | N | Y (transport) | N | NA | N | N
Sable,1999^30^ | N (health care system) | Y (transport) | Y | N | Y (travel only) | N | N | N | N

Evidence Table 10. Studies of cost for all study areas, Part 4 - Satisfaction and comments

Part 4 - Satisfaction and comments
Source | Satisfaction | Comments
Rendina et al. 1997^29^ and 1998^28^ | N | reduced time needed for report on echocardiogram, 31 patients excluded from length of stay estimate (no reason), require about 600 patients (12 years to recruit) for adequate power, no other outcomes including adverse events
Finley et al., 1997^27^ | N | only case series, transport is only part of episode of care, no comparison group, impact of unreadable images not described
Sable,1999^30^ | N | if reduce emergency transport via helicopter will more than offset costs of telemedicine equipment; lower (total?) costs for echocardiogram interpretation and inpatient stays during telemedicine period than before but no indication of number of patients, severity of condition or outcome (making interpretation of this result problematic)