# Bibliography

Aarnio P, Lamminen H, Lepisto J, et al A prospective study of teleconferencing for orthopaedic consultations J Telemed Telecare 1999 5(1):62 6 10505371
Aarnio P, Rudenberg H, Ellonen M, et al User satisfaction with teleconsultations for surgery J Telemed Telecare 2000 6(4):237 41 11027127
Aas IH Working with telemedicine: user characteristics and attitudes J Telemed Telecare 2000 6(Suppl 1):S66 8 10793976
Abdullah BJ, Ng KH, Pathmanathan R The impact of teleradiology in clinical practice-a Malaysian perspective Med J Malaysia 1999 54(2):169 74 10972025
Abidi SS. TIDE: an intelligent home-based healthcare information & diagnostic environment. Stud Health Technol Inform. 1999;68:720-5. [pmid: 10724989].
Adams A Telemedicine in Texas Texas Med 2000 96(1):48 51
Ades PA, Pashkow FJ, Fletcher G, et al A controlled trial of cardiac rehabilitation in the home setting using electrocardiographic and voice transtelephonic monitoring Am Heart J 2000 139(3):543 8 10689271
Afset J, Lunde P, Rasmussen K Accuracy of routine echocardiographic measurement made by an inexperienced examiner through tele-instruction J Telemed Telecare 1996 2(3):148 54 9375049
Agha Z, Weinstein RS, Dunn BE Cost minimization analysis of telepathology Am J Clin Pathol 1999 112(4):470 8 10510670
Agius RM, Bagnall G Development and evaluation of the use of the Internet as an educational tool in occupational and environmental health and medicine Occup Med (Lond) 1998 48(5):337 43 9876418
Agroyannis B, Fourtounas C, Romagnoli G, et al Telemedicine technology and applications for home hemodialysis Int J Artif Organs 1999 22(10):679 83 10585132
Ahmed A, Slosberg E, Prasad P, et al The successful use of telemedicine in acute variceal hemorrhage [letter] J Clin Gastroenterol 1999 29(2):212 3
Aires LM, Finley JP Telemedicine activity at a Canadian university medical school and its teaching hospitals J Telemed Telecare 2000 6(1):31 5 10824388
al-Taei MK, Pan Y, Lu DM An Internet-based telediagnosis system for Chinese medicine J Telemed Telecare 2000 6(Suppl 1):S63 5
Alemi F, Mosavel M, Stephens RC, et al Electronic self-help and support groups Med Care 1996 34(10 Suppl):OS32 44 8843935
Alemi F, Stephens R Computer services to patients' homes through their telephones. Application to other disease management efforts Med Care 1996 34(10 Suppl):OS52 5 8843937
Alemi F, Stephens RC Computer services for patients. Description of systems and summary of findings Med Care 1996 34(10 Suppl):OS1 9 8843932
Alemi F, Stephens RC, Javalghi RG, et al A randomized trial of a telecommunications network for pregnant women who use cocaine Med Care 1996 34(10 Suppl):OS10 20 8843933
Alemi F, Stephens RC, Muise K, et al Educating patients at home. Community Health Rap Med Care 1996 34(10 Suppl):OS21 31 8843934
Alemi F, Walker LR, Minter R Internet course on total quality management J Health Admin Educ 1998 16(3):267 82
Alexander M Telemedicine in Australia. 1: The health-care system and the development of telemedicine J Telemed Telecare 1995 1(4):187 95 9375142
Alkhateeb A, Takahashi T, Mandil S, et al The changing role of health care IC card systems Comput Methods Programs Biomed 1999 60(2):83 92 10505964
Allen A, Roman L, Cox R, et al Home health visits using a cable television network: user satisfaction J Telemed Telecare 1996 2(Suppl 1):92 4 9375106
Anderson JG The business of Cyberhealthcare MD Comput 1999 16(6):23 5 10658397
Anderson JG, Casebeer LL, Kristofco RE. Medcast: evaluation of an intelligent pull technology to support the information needs of physicians. Proc AMIA Ann Symposium. 1999:466-70.
Anderson MF, Moazamipour H, Hudson DL, et al The role of the Internet in Med Decis Making Int J Med Inform 1997 47(1-2):43 9 9506391
Angaran DM Telemedicine and telepharmacy: current status and future implications Am J Health Syst Pharm 1999 56(14):1405 26 10428449
Angood PB, Merrell RC Musings on Internet-based telemedicine Telemed J 1998 4(4):379 81 10220480
Anonymous AHCPR offers resources for consumers, providers, and health agencies. Agency for Health Care Policy and Research [news] Public Health Rep 1999 114(2):
Anonymous Can you meet information needs of 'new seniors' in Medicare risk? Public Sect Contract Rep 1998 4(11):172 4
Anonymous Decide to go on-line for the health of your business and your patients Healthc Benchmarks 1999 6(3):25 9 10346176
Anonymous Despite homecare success, technology switch over inside hospital gets mixed reviews Health Care Cost Reengineering Rep 1998 3(1):7 9 10176626
Anonymous E-doc approach opens lines to patients J Ark Med Soc 2000 96(8):302 4 10659534
Anonymous Easy-chair entry: Internet check-in is not far off Patient Focus Care Satisf 1999 7(11):129 31 10662134
Anonymous Getting ready for surgery online OR Manager 1999 15(8):24 6
Anonymous Guidelines for preventing catheter associated urinary tract infections-on Internet for consultation Communi Dis Rep CDR Wkly 2000 10(17):
Anonymous Handheld computers are key to improving homecare operations for Colorado provider Health Care Cost Reengineering Rep 1998 3(1):5 7 10176625
Anonymous Health care on the Internet Mark Health Serv 1999 19(2).
Anonymous Hospital, home health, assisted living stocks down, e-commerce, lab stocks up in 1999 [news] Health Care Strateg Manage 2000 18(2).
Anonymous HOST conference finds health care ready for Internet. Healthcare Open Systems & Trials [news] Telemed Virtual Real 1998 3(2).
Anonymous House calls through the Web Telemed Today 1999 7(5).
Anonymous ICNP in Europe: Telenurse Int Nurs Rev 1996 43(6):188 9 8961033
Anonymous Maine area ties up to telemedicine project [news] Telemed Virtual Real 1998 3(10).
Anonymous Medical image transmission tops list of telemedicine applications Biomed Instrum Technol 1999 33(4):
Anonymous National Library of Medicine grants for telemedicine research [news] Telemed Virtual Real 1998 3(1):4 5 10176382
Anonymous New guide discusses telemedicine for the home [news] Telemed Virtual Real 1998 3(3).
Anonymous The Ninth Annual HIMSS Leadership Survey Healthcare Information and Management Systems Society. Healthcare Inform 1998 15(5):55 8
Anonymous OASIS resources Home Healthc Nurse 1999 17(4):213 4 10382433
Anonymous Ready for the empowered consumer? Providers need retailer's attitude Healthc Benchmarks 1999 6(1):1 4 10345803
Anonymous Recommended healthcare websites Cost Qual Q J 1999 5(3).
Anonymous Report identifies barriers to providing health care on the Internet [news] Am J Health Syst Pharm 2000 57(10):939 40 10832490
Anonymous Telecommunications in healthcare: a primer Health Devices 1997 26(7):264 85 9251916
Anonymous TeleHealth providers urged to plan for applications [news] Telemed Virtual Real 1998 3(2).
Anonymous Unique collaboration targets delays: learn from the impressive results of 31 EDs Ed Management 1998 10(10):109 16 10185246
Anonymous What's happening in information systems technology that is reshaping health care delivery, and how might it assist in infection prevention and control? Am J Infect Control 1996 24(6):476 80 8974174
Anonymous The wired health system: telemedicine comes of age Health Care Cost Reengineering Rep 1998 3(8):121 3 10182722
Apple SL, Schmidt JH Technique for neurosurgically relevant CT image transfers using inexpensive video digital technology Surg Neurol 2000 53(5):411 6 10874138
Appleby C Net gain or net loss? Health care consumers become Internet savvy Trustee 1999 52(2):20 3 10538972
Armstrong Technology is 1997's 'differentiator' Health Manage Technol 1997 18(2).
Armstrong B, Patterson C Hardware: the power beneath it all Healthcare Inform 1997 14(2):86 9
Arnold M, Halsey JF, Janzen VK, et al Testing on demand. Are laboratories and consumers ready? MLO Med Lab Obs 2000 32(3):22 6
Ashcroft RE, Goddard PR Ethical issues in teleradiology Br J Radiol 2000 73(870):578 82 10911778
Atkinson PR, Bingham J, McNicholl BP, et al Telemedicine and cardiopulmonary resuscitation: the value of video-link and telephone instruction to a mock bystander J Telemed Telecare 1999 5(4):242 5 10829375
Atlas I, Granai CO, Gajewski W, et al Videoconferencing for gynaecological cancer care: an international tumour board J Telemed Telecare 2000 6(4):242 4 11027128
Bader SA, Braude RM "Patient informatics": creating new partnerships in Med Decis Making Acad Med 1998 73(4):408 11 9580718
Baff M Enhancing home care's off-site operations through Internet technology Health Care Innov 1997 7(3):18 20 10167697
Bai J, Zhang Y, Shen D, et al A portable ECG and blood pressure telemonitoring system IEEE Eng Med Biol Mag 1999 18(4):63 70 10429903
Baigent MF, Lloyd CJ, Kavanagh SJ, et al Telepsychiatry: 'tele' yes, but what about the 'psychiatry'? J Telemed Telecare 1997 3(Suppl 1):3 5 9218364
Bailes JE. Present technology and future applications. Clin Neurosurg. 1999;45:192-201. [pmid: 10461517].
Bailey J, Dickson N Analyzing home care information system needs Caring 1993 12(7):34 7
Bailey M Legal issues relating to telemedicine in Canada's publicly funded health-care system J Telemed Telecare 2000 6(Suppl 1):S140 2 10794000
Baker SR, Festa S The use of teleradiology in an emergency setting with speculation on the near future Radiol Clin North Am 1999 37(5):1035 44 10494282
Bakker AR, Barber B, Pellikka RT Overall observations, conclusions and recommendations Int J Biomed Comput 1996 43(1-2):149 52 8960936
Balaban D Data security. Raising the drawbridge Health Data Manag 1998 6(8):81 2 10181954
Baldwin FD The Starbright program showing kids a heavenly good time Penn Med 2000Suppl:
Ball CJ, McLaren PM, Summerfield AB, et al A comparison of communication modes in adult psychiatry J Telemed Telecare 1995 1(1):22 6 9375115
Ball CJ, Scott N, McLaren PM, et al Preliminary evaluation of a Low-Cost VideoConferencing (LCVC) system for remote cognitive testing of adult psychiatric patients Br J Clin Psychol 1993 32(Pt 3):303 7 8251960
Ball MJ, Douglas JV Health information networks MEDINFO 1995 8(Pt 2):1465 9 8591475
Banta HD, Sanes JR Assessing the social impacts of medical technologies J Community Health 1978 3(3):245 58 721958
Baquet CR An overview of telemedicine J Assoc Acad Minor Phys 1997 8(1):2 10 9048466
Barber B Patient data and security: an overview Int J Med Inform 1998 49(1):19 30 9723797
Bard MR Information technology-the new paradigm shift in healthcare J Cardiovasc Manag 1996 7(6):19 22 10162111
Barnett AA Is knowledge really power for patients? Bus Health 1995 13(5):29 30 10164495
Barro S, Presedo J, Castro D, et al Intelligent telemonitoring of critical-care patients IEEE Eng Med Biol Mag 1999 18(4):80 8
Bashshur R, Panitch K, Peredina D, et al An update on telemedicine Patient Care 2000(March 30):96 109
Bauer JC How telemedicine is rearranging our universe Mich Health Hosp 1999 35(6):12 4 10724700
Baur C Limiting factors on the transformative powers of e-mail in patient-physician relationships: a critical analysis Health Commun 2000 12(3):239 59 10938915
Bazzoli F The allure of the Internet Health Data Manag 1995 3(6):24 6 10143845
Beach M, Goodall I, Miller P Evaluating telemedicine for minor injuries units J Telemed Telecare 2000 6(Suppl 1):S90 2
Beals DA, Fletcher JR Telemedicine and pediatric surgery Sem Pediatr Surg 2000 9(1):40 7
Beauregard D, Beauregard G The intellectual property cookbook: a guide for the novice health-care telemedicine provider working with industry J Telemed Telecare 2000 6(Suppl 1):S107 9 10793990
Beauregard D, Lewis J, Piccolo M, et al Diagnosis of glaucoma using telemedicine-the effect of compression on the evaluation of optic nerve head cup-disc ratio J Telemed Telecare 2000 6(Suppl 1):S123 5 10793995
Bell DS, Fonarow GC, Hays RD, et al Self-study from web-based and printed guideline materials. A randomized, controlled trial among resident physicians Ann Intern Med 2000 132(12):938 46 10858176
Bellon E, Van Cleynenbreugel J, Delaere D, et al. Experimental teleradiology. Novel telematics services using image processing, hypermedia and remote cooperation to improve image-based Med Decis Making. J Telemed Telecare. 1995;1:100-110. [pmid: 9375127].
Bellon E, Van Cleynenbreugel J, Suetens P, et al Computer-assisted multimedia communication of radiologic reports Acad Radiol 1995 2(1):79 82 9419530
Belmont JM, Mattioli LF, Goertz KK, et al Evaluation of remote stethoscopy for pediatric telecardiology Telemed J 1995 1(2):133 49 10165332
Benger J A review of telemedicine in accident and emergency: the story so far J Accid Emerg Med 2000 17(3):157 64 10819375
Bennett WF, Spigos DG, Vaswani KV, et al Cable modem access to picture archiving and communication system images using a web browser over the Internet J Digit Imaging 2000 13(2 Suppl 1):93 6 10847372
Benson BW Teleradiology Dent Clin North Am 2000 44(2):359 70 10740773
Berek B, Canna M Telemedicine on the move: health care heads down the information superhighway Hosp Technol Ser 1994 13(6):1 65
Bergman R Computers make 'house calls' to patients Hospitals 1993 67(10):
Bergman R Stone age solutions? IS vendors aren't keeping pace with today's delivery needs Hosp Health Netw 1995 69(3):26 8, 30, 32 7842023
Bergmo TS. A cost-minimization analysis of a realtime teledermatology service in northern Norway. J Telemed Telecare. 2000;6:273-277. [pmid: 11070588].
Bergmo TS An economic analysis of teleconsultation in otorhinolaryngology J Telemed Telecare 1997 3(4):194 9 9614733
Bergmo TS, Breivik E, Pedersen S [Will the use of still image electronic referrals save costs?] Tidsskr Nor Laegeforen 2000 120(15):1777 80 10904666
Berliner H Information management. Key punch Health Serv J 1998 108(5631):
Berman AJ Supporting the home care client receiving chemotherapy Home Care Provid 1999 4(2):81 5; quiz 86-7 10418401
Berner ES, Partridge EE, Baum SK The effects of the PDQ patient information file (PIF) on patients' knowledge, enrollment in clinical trials, and satisfaction J Cancer Educ 1997 12(2):121 5 9229276
Betancourt DR, Roca AA, Borges OF Medical image transmission on low-speed networks J Digit Imaging 2000 13(2 Suppl 1):215 6 10847407
Biancamano J, Caniff-Gilliam C, Israel MD, et al Top executives share I/S strategies ... Anderson Consulting Health Management Conference Health ManageTechnol 1996 17(6):13 4
Biesecker LG, DeRenzo EG Internet solicitation of research subjects for genetic studies [letter] Am J Hum Genet 1995 57(5):1255 6 7485182 1801362
Bigley J. The electronic data interchange: avoiding potholes to add value & power for payors & providers. Infocare. p 1995.
Bihun TA Using Quick Response to manage the material flow Hosp Mat Manage Q 1995 17(2):1 5
Birch K, Rigby M, Roberts R Putting the 'tele' into health-care effectively J Telemed Telecare 2000 6(Suppl 1):S113 5 10793992
Bjorn N. Internet provides fast and inexpensive information to home care. Stud Health Technol Inform. 1999;68:958-60. [pmid: 10725042].
Blignault I Multipoint videoconferencing in health: a review of three years' experience in Queensland, Australia Telemed J 2000 6(2):269 74 10957740
Blobel B Onconet: a secure infrastructure to improve cancer patients' care Eur J Med Res 2000 5(8):360 8 10958770
Blobel B, Pharow P, Engel K, et al. Communication security in open health care networks. Stud Health Technol Inform. 1999;68:291-6. [pmid: 10724890].
Blouin AS, Brent NJ Happy Y2K. New and old challenges for the nurse administrator J Nurs Admin 2000 30(6):292 4
Bluming A, Mittelman PS Los Angeles Free-Net: an experiment in interactive telecommunication between lay members of the Los Angeles community and health care experts [see comments] BullMed Libr Assoc 1996 84(2):217 22
Boll R Community health information networks: paving the country roads J AHIMA 1996 67(4):61 3 10155783
Bonge LE, Brye P, Butkovich T See me, hear me, heal me. How telecommunications will transform tomorrow's health facilities-regardless of reform Health Facil Manage 1994 7(9):30 2
Bottles K The information revolution: opportunities and pitfalls for patients and providers Phys Exec 2000 26(1):20 1
Bowman A, Gordon AS, Grice W, et al A global perspective: technology in home care. Discussion Caring 1997 16(7):14 6
Boydell L, McAllister B European prototype for integrated care (EPIC) Comput Methods Programs Biomed 1994 45(1-2):47 9 7889763
Bradley J The changing face of health information and health information work: a conceptual framework BullMed Libr Assoc 1996 84(1):1 10
Braseth C, Younger B Centered care: focusing on the patient Healthcare Inform 1995 12(5):40 2
Bratton RL, Cody C Telemedicine applications in primary care: a geriatric patient pilot project Mayo Clin Proc 2000 75(4):365 8 10761491
Braun RP, Meier M, Pelloni F, et al Teledermatoscopy in Switzerland: a preliminary evaluation J Am Acad Dermatol 2000 42(5 Pt 1):770 5 10775852
Bregman D, Levi L [Use of Intranet in the hospital setting] Harefuah 1998 134(10):753 7, 832 10909629
Brennan CP Managed care and health information networks J Health Care Finance 1995 21(4):1 5 7583779
Brennan JA, Kealy JA, Gerardi LH, et al A randomized controlled trial of telemedicine in an emergency department J Telemed Telecare 1998 4(Suppl 1):18 20
Brennan JA, Kealy JA, Gerardi LH, et al Telemedicine in the emergency department: a randomized controlled trial J Telemed Telecare 1999 5(1):18 22 10505365
Brennan PF Characterizing the use of health care services delivered via computer networks J Am Med Inform Assoc 1995 2(3):160 8 116250 7614117
Brennan PF Computer networks: new tools for nursing practice [editorial] Appl Nurs Res 1996 9(4):159 60 8961571
Brennan PF ComputerLink: computer networks and community health connections Nurs Dyn 1993 2(1):9 15 8124455
Brennan PF. The ComputerLink projects: a decade of experience. Stud Health Technol Inform. 1997;46:521-6. [pmid: 10175453].
Brennan PF. Differential use of computer network services. Proc Ann Symposium Comput App Med Care. 1993:27-31.
Brennan PF The future of clinical communication in an electronic environment Holist Nurs Pract 1996 11(1):97 104 8945178
Brennan PF Health informatics and community health: support for patients as collaborators in care Methods Inf Med 1999 38(4-5):274 8 10805012
Brennan PF Telehealth: bringing health care to the point of living [editorial; comment] Med Care 1999 37(2):115 6 10024115
Brennan PF, Caldwell B, Moore SM, et al. Designing HeartCare: custom computerized home care for patients recovering from CABG surgery. Proceedings/AMIA Annual Symposium. 1998:381-5.
Brennan PF, Moore SA, Smyth KA The effects of a special computer network on caregivers of persons with Alzheimer's disease Nurs Res 1995 44(3):166 72 7761293
Brennan PF, Moore SM Networks for home care support: the ComputerLink project Caring 1994 13(8):64 6
Brennan PF, Ripich S Use of a home-care computer network by persons with AIDS Int J Technol Assess Health Care 1994 10(2):258 72 8034405
Brennan PF, Strombom I Improving health care by understanding patient preferences: the role of computer technology J Am Med Inform Assoc 1998 5(3):257 62 61299 9609495
Brennecke R, Hammermeister K Computers and the Internet in cardiac care. Will cardiology rise to this extraordinary opportunity? Eur Heart J 1997 18(9):1382 4 9458442
Briggs JS Measuring the readership of a health-related Website J Telemed Telecare 2000 6(Suppl 2):S2 5 10975081
Briggs JS, Early GH Internet developments and their significance for healthcare Med Inform Internet Med 1999 24(3):149 64 10654809
Brink S Digital house calls. How to get medical advice via computer US News World Rep 1993 115(20):76 7 10130167
Briscoe D, Adair CF, Thompson LD, et al Telecytologic diagnosis of breast fine needle aspiration biopsies. Intraobserver concordance Acta Cytol 2000 44(2):175 80 10740603
Brown G Technology in nurse education: a communication teaching strategy ABNF Journal 1999 10(1):9 13 10335136
Brown MS Industry information technology trends Caring 1997 16(12):68 72 10176259
Brown NA Five years' experience with the Telemedicine Information Exchange J Telemed Telecare 2000 6(Suppl 1):S110 2 10793991
Brown R, Pain K, Berwald C, et al Distance education and caregiver support groups: comparison of traditional and telephone groups J Head Trauma Rehabil 1999 14(3):257 68 10381978
Browne MW, Hines JF, Satin AJ, et al Videoteleconferencing for administration of a multisite obstetrics and gynecology core clerkship Obstet Gynecol 2000 95(3):461 3 10711564
Brownsell SJ, Bradley DA, Bragg R, et al Do community alarm users want telecare? J Telemed Telecare 2000 6(4):199 204 11027119
Bruckmann A, Uhl A Selective medical image compression techniques for telemedical and archiving applications Comput Biol Med 2000 30(3):153 69 10758230
Bruegel R, Andrew W The CPR: patient empowerment paradigm Healthcare Inform 1996 13(10):26 8
Brunner BK Health care-oriented telecommunications: the wave of the future Top Health Inf Manage 1993 14(1):54 61 10127701
Bruno D, Delvecchio FC, Preminger GM Digital still image recording during video endoscopy J Endourol 1999 13(5):353 6; discussion 356-7 10446795
Bryant J Cost minization analysis of telepathology: a critical review [letter] Am J Clin Pathol 2000 113(6):902 5 10874892
Buffone GJ, Beck JR Facilitation of health care delivery through enhanced communications Int J Biomed Comput 1994 34(1-4):349 55 8125649
Buist A, Coman G, Silvas A, et al An evaluation of the telepsychiatry programme in Victoria, Australia J Telemed Telecare 2000 6(4):216 21 11027122
Bunschoten B Measuring outcomes Health Data Manag 1996 4(6):40 2
Burgess LP, Holtel MR, Syms MJ, et al Overview of telemedicine applications for otolaryngology Laryngoscope 1999 109(9):1433 7 10499050
Burnett AC, Winyard G Clinical audit at the heart of clinical effectiveness J Qual Clin Pract 1998 18(1):3 19 9563557
Bysinger B Using the Internet to support provider-patient collaboration Health Manage Technol 1997 18(1):44 5
Cai W, Feng DD, Fulton R Content-based retrieval of dynamic PET functional images IEEE Trans Inf Technol Biomed 2000 4(2):152 8 10866414
Cain NJ, Fuller HJ The hospital library online-a point of service for consumers and hospital staff: a case study Bull Med Libr Assoc 1999 87(3):261 3 226581 10427424
Caldwell DH, Jr Computer databases and Internet sites J Health Law 1998 31(3):333 60 10620834
Camara JG, Zabala RR, Henson RD, et al Teleophthalmology: the use of real-time telementoring to remove an orbital tumor Ophthalmology 2000 107(8):1468 71 10919891
Campbell S Health care organizations are listening to the newly-found voice of the consumer Health Care Strateg Manage 1998 16(3):14 5
Campbell T, Martel RF A programme management model for the Nova Scotia telemedicine network J Telemed Telecare 1999 5(Suppl 1):S72 4 10534850
Caramella D, Reponen J, Fabbrini F, et al Teleradiology in Europe Eur J Radiol 2000 33(1):2 7 10674783
Cardno EJ Managing the 'fit' of information and communication technology in community health: a framework for decision making J Telemed Telecare 2000 6(Suppl 2):S6 8 10975082
Carnall D Digital radio relays text to remote doctors and nurses in Africa [news] BMJ 2000 320(7247):27404
Carrigan M The future of health care information systems Hosp Mat Manage Q 1993 15(1):1 13
Cartwright W, Dalton K, Swindells H, et al. Objective measurement of anxiety in hypertensive pregnant women managed in hospital and in the community. Br J Obstet Gynaecol. 1992;99:182-185. [pmid: 1606113].
Carty B Technology as a tool to transform practice Imprint 1996 43(3):40 1, 43 8850850
Casey F, Brown D, Corrigan N, et al Value of a low-cost telemedicine link in the remote echocardiographic diagnosis of congenital heart defects J Telemed Telecare 1998 4(Suppl 1):46 8 9640733
Casey F, Brown D, Craig BG, et al Diagnosis of neonatal congenital heart defects by remote consultation using a low-cost telemedicine link J Telemed Telecare 1996 2(3):165 9 9375052
Casey FA Telemedicine in paediatric cardiology Arch Dis Child 1999 80(6):497 9 10331995
Casper GR, Calvitti A, Brennan PF, et al ComputerLink: the impact of a computer network on Alzheimer's caregivers' decision-making confidence and skill MEDINFO 1995 8(Pt 2):
Cassidy K How to assess and intervene in domestic violence situations Home Healthc Nurse 1999 17(10):664 71; quiz 672 10818841
Celler BG, Earnshaw W, Ilsar ED, et al Remote monitoring of health status of the elderly at home. A multidisciplinary project on aging at the University of New South Wales Int J Biomed Comput 1995 40(2):147 55 8847123
Celler BG, Lovell NH, Chan DK The potential impact of home telecare on clinical practice Med J Aust 1999 171(10):518 21 10816699
Chae YM, Park HJ, Cho JG, et al The reliability and acceptability of telemedicine for patients with schizophrenia in Korea J Telemed Telecare 2000 6(2):83 90 10824375
Chan FY, Soong B, Lessing K, et al Clinical value of real-time tertiary fetal ultrasound consultation by telemedicine: preliminary evaluation Telemed J 2000 6(2):237 42 10957736
Cheng GY, Lam LM Information-seeking behavior of health professionals in Hong Kong: a survey of thirty-seven hospitals Bull Med Libr Assoc 1996 84(1):32 40 226122 8938328
Chepesiuk R Making house calls: using telecommunications to bring health care into the home Environ Health Perspect 1999 107(11):A556 60 10544168
Chesanow N How one group builds market leadership Med Econ 1998 75(4):84 6 10176961
Chesnut R, Carney N, Maynard H, et al. Rehabilitation for Traumatic Brain Injury. Evidence report no. 2 (Contract 290-97-0018 to Oregon Health Sciences University). Rockville, MD: Agency for Health Care Policy and Research; 1999 1999.
Chi CH, Chang I, Wu WP Emergency department-based telemedicine Am J Emerg Med 1999 17(4):408 11 10452445
Chin TL Building a consumer brand Health Data Manag 1999 7(4):69 70 10351307
Chin TL Call centers improve service, carry out managed care goals Health Data Manag 1998 6(2):122 4 10177784
Chin TL Managed care. Patient education at the crossroads Health Data Manag 1997 5(11).
Cho MK Guidelines for advertising on health web sites: who's guarding the Koop [see comments] West J Med 2000 172(4):230 2 10778369 1070825
Choi J, Kim Y, Lee S, et al Features for a B-ISDN telemedicine system and its application MEDINFO 1998 9(Pt 1):307 10 10384468
Christmas WA, Turner HS, Crothers L Should college health providers use e-mail to communicate with their patients? Two points of view J Am College Health 2000 49(1):39 43
Cigich SM Health care converges: a new era in patient care emerges Med Group Manage J 2000 47(2):10 1 10787721
Cimino JJ Data storage and knowledge representation for clinical workstations Int J Biomed Comput 1994 34(1-4):185 94 8125631
Clark DJ Old wine in new bottles: delivering nursing in the 21st century J Nurs Scholar 2000 32(1):11 5
Clarkson MD. An evaluation of the DuPont Linx NS400 Networking System. London, England: Department of Health. 1996;37. [pmcid: 164419].
Coates V. Dilemmas in determining a research agenda for direct communications with patients. In: Healthcare technology choices under managed care: communicating directly with patients and their clinicians: proceedings of a conference, November. 1996;1997:111-6.
Cochrane JD. Healthcare @ the speed of thought. Integr Healthc Rep. 1999.
Coiera E The Internet's challenge to health care provision [editorial] BMJ 1996 312(7022):3 4 8555856
Coile RC, Jr Challenges for Phys Execs in the millennium marketplace Phys Exec 1999 25(1):8 13
Coile RC, Jr The digital transformation of health care Phys Exec 2000 26(1):8 15
Coile RC, Jr Seniors' demographic revolution redefines health care marketing, financing, and delivery Russ Coiles Health Trends 1998 10(9):4 9
Coile RC, Jr Top 10 health care trends for 1998. Tomorrow's trends will be consumerism, cyberhealth, and co-opetition Russ Coiles Health Trends 1998 10(3):3 12
Coile RC, Jr Top 10 trends for health care information systems Russ Coiles Health Trends 1998 11(1):7 12 10339072
Coile RC, Jr., Bauer J, Trusko B Health care 2010's "long boom" trends Russ Coiles Health Trends 2000 12(6):6 12 11066232
Coile RC, Jr., Howe RC The Internet: changing the way consumers receive health care Russ Coiles Health Trends 1999 11(9):9 12 10539462
Coile RC, Jr., Trusko BE Healthcare 2020: the new rules of society Health Manage Technol 1999 20(8).
Colby M Sorting out the Baby Bells' strategies Health Data Manag 1994 2(4):18 26 10141190
Collen MF Historical evolution of preventive medical informatics in the USA Methods Inf Med 2000 39(3):204 7 10992744
Collins J Middleware. The reality check for mobile healthcare Healthcare Inform 1998 15(3).
Collins K, Nicolson P, Bowns I, et al General practitioners' perceptions of store-and-forward teledermatology J Telemed Telecare 2000 6(1):50 3 10824392
Connors HR Telecommunications and health care Issues 1997 18(2):
Conrad N, Haque R, Cockerell CJ Delivery of dermatopathologic health care in the twenty-first century Dermatol Clin 2000 18(2):241 9, ix 10791151
Consiglio G Healthcare and the Internet: a friendship in the works Healthcare Inform 1996 13(7).
Cook J, Austen G, Stephens C Videoconferencing: what are the benefits for dental practice? Br Dent J 2000 188(2):67 70 10689767
Cooke FJ, Holmes A E-mail consultations in international health [letter] Lancet 2000 356(9224):
Cooper JB, Barron D, Blum R, et al Video teleconferencing with realistic simulation for Med Educ J Clin Anesth 2000 12(3):256 61 10869931
Corr P, Couper I, Beningfield SJ, et al A simple telemedicine system using a digital camera J Telemed Telecare 2000 6(4):233 6 11027126
Corro D, Beyer J, Feinberg E Technology and the care of the elderly Healthplan 1998 39(4):19 23
Cosmos C Federal regulators sound warnings about eHealth, cite areas of potential regulation Telemed Today 2000 8(2):27 9 10947511
Coulthard P, Kazakou I, Koran R, et al Referral patterns and the referral system for oral surgery care. Part 2: The referral system and telemedicine Br Dent J 2000 188(7):388 91 10816929
Cowley G The rise of cyberdoc Newsweek 1994 124(13):54 5 10136880
Cox CG, White D, Brinson H, et al Distance learning: health education for ninth-grade students J Telemed Telecare 2000 6(Suppl 2):S8 10 10975083
Coyne KP, Dye R The competitive dynamics of network-based businesses Harvard Bus Rev 1998 76(1):99 109
Craig J, Chua R, Russell C, et al The cost-effectiveness of teleneurology consultations for patients admitted to hospitals without neurologists on site. 1: A retrospective comparison of the case-mix and management at two rural hospitals J Telemed Telecare 2000 6(Suppl 1):S46 9 10793970
Craig J, Chua R, Wootton R, et al A pilot study of telemedicine for new neurological outpatient referrals J Telemed Telecare 2000 6(4):225 8 11027124
Craig J, Russell C, Patterson V, et al User satisfaction with realtime teleneurology J Telemed Telecare 1999 5(4):237 41 10829374
Craig JJ, McConville JP, Patterson VH, et al Neurological examination is possible using telemedicine J Telemed Telecare 1999 5(3):177 81 10628033
Creswell J What the heck is Healtheon? [news] Fortune 2000 141(4):175 6 10915526
Cross M Blue Cross/Blue Shield plans take the lead in building health information networks Health Data Manag 1996 4(8):59 60 10159607
Cross M Home care giant builds an IT plan Health Data Manag 1997 5(3):38 40 10166225
Cross M Referrals online and on time Health Data Manag 1999 7(9):105 7 10621037
Cross MA Disney's city of the future Health Data Manag 1997 5(10):42 5 10175742
Crossley N Glorious technicolour? It's not that black and white Nurs Times 1999 95(45):44 6 11000800
Crowe BL, Hailey DM, Carter R Assessment of costs and benefits in the introduction of digital radiology systems Int J Biomed Comput 1992 30(1):17 25 1551733
Crowe BL, Hailey DM, de Silva M Teleradiology at a children's hospital: a pilot study J Telemed Telecare 1996 2(4):210 6 9375061
Cupito MC Enterprise integration. A lesson from trains, boats and planes Health Manage Technol 1998 19(5):24 6
Curran VR, Church JG A study of rural women's satisfaction with a breast cancer self-help network J Telemed Telecare 1999 5(1):47 54 10505369
Currell R, Urquhart C, Wainwright P, et al. Telemedicine versus face to face patient care: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews [computer file] 2000(2):CD002098.
Curry GR, Harrop N The Lancashire telemedicine ambulance J Telemed Telecare 1998 4(4):231 8 10505360
Cuzzani O, Bromwich M, Penno E, et al The effect of transmission bandwidth on the quality of ophthalmological still and video images J Telemed Telecare 2000 6(Suppl 2):S11 3 10975084
D'Souza M, Shah D, Johal B, et al Dermaclinic: preliminary triage by GP specialoids? [letter] Br J Gen Pract 2000 50(452):
D'Souza R Telemedicine for intensive support of psychiatric inpatients admitted to local hospitals J Telemed Telecare 2000 6(Suppl 1):S26 8 10793963
Dannenfeldt D Giving home care nurses a hand [published erratum appears in Health Data Manag 1994 Jul-Aug;2(6):14] Health Data Manag 1994 2(4):57 8
Darkwa O An exploratory survey of the applications of telemedicine in Ghana J Telemed Telecare 2000 6(3):177 83 10912338
Davidhizar R Caregiving from a distance Hosp Top 1999 77(1):9 13 10847924
Davies B A review of robotics in surgery. Proceedings of the Institution of Mechanical Engineers Part H - J Eng Med 2000 214(1):129 40
Davison KP, Pennebaker JW, Dickerson SS Who talks? The social psychology of illness support groups Am Psychol 2000 55(2):205 17 10717968
Dawes BS Perioperative nurses are striving to provide the best of the best [editorial] AORN J 1998 67(2):338 340 9505116
Dawson A, Cohen D, Candelier C, et al Domiciliary midwifery support in high-risk pregnancy incorporating telephonic fetal heart rate monitoring: a health technology randomized assessment J Telemed Telecare 1999 5(4):220 30 10829372
Dawson PJ, Johnson JG, Edgemon LJ, et al Outpatient frozen sections by telepathology in a Veterans Administration medical center Hum Pathol 2000 31(7):786 8 10923913
Dawson R, Gilbertson J, Kim S, et al Pathology imaging on the Web. Extending the role of the pathologist as educator to patients Clin Lab Med 1999 19(4):849 66, vii 10572719
de Lusignan S, Althans A, Wells S, et al A pilot study of radiotelemetry for continuous cardiopulmonary monitoring of patients at home J Telemed Telecare 2000 6(Suppl 1):S119 22 10793994
de Lusignan S, Wells S, Thiru K Stopping antihypertensive drugs in general practice [letter] Br J Gen Pract 2000 50(454):407 8
De Moor GJ, Segers DF, Schilders L Towards a meta-syntax for medical edi Int J Biomed Comput 1994 34(1-4):319 30 8125645
DeBrota DJ In front of us Int J Biomed Comput 1994 34(1-4):131 5 8125626
Deering MJ, Harris J Consumer health information demand and delivery: implications for libraries [see comments] Bull Med Libr Assoc 1996 84(2):209 16 299407 8826626
DeGeorges KM Surfing the consumer Web AWHONN Lifelines 1999 3(1):53 4
Degoulet P, Safran C, Bowers GH Design and processing issues for the health care professional workstation: summary and recommendations Int J Biomed Comput 1994 34(1-4):241 7 8125635
Deitsch SE, Frueh BC, Santos AB Telepsychiatry for post-traumatic stress disorder J Telemed Telecare 2000 6(3):184 6 10912339
Della Mea V Telepathology and other telemedicine fields: lessons to learn Adv Clin Pathol 1999 3(4):107 9
Della Mea V, Cortolezzis D, Beltrami CA The economics of telepathology-a case study J Telemed Telecare 2000 6(Suppl 1):S168 9 10794009
Demartines N, Freiermuth O, Mutter D, et al Knowledge and acceptance of telemedicine in surgery: a survey J Telemed Telecare 2000 6(3):125 31 10912328
Demartines N, Mutter D, Marescaux J, et al Preliminary assessment of the value and effect of expert consultation in telemedicine J Am Coll Surg 2000 190(4):466 70 10757385
Demartines N, Mutter D, Vix M, et al Assessment of telemedicine in surgical education and patient care Ann Surg 2000 231(2):282 91 10674622 1420998
Demartines N, Otto U, Mutter D, et al An evaluation of telemedicine in surgery: telediagnosis compared with direct diagnosis Arch Surg 2000 135(7):849 53 10896381
Demichelis F, Berloffa F, Eccher C, et al Design and initial implementation of a regional tele-oncology project J Telemed Telecare 2000 6(Suppl 1):S71 3 10793978
Demiris G, Speedie S, Finkelstein S. A questionnaire for the assessment of patients' impressions of the risks and benefits of home telecare. J Telemed Telecare. 2000;6:278-284. [pmid: 11070589].
Denton JS, Higgins J. The hospice experience with a CPR and the Internet. In: Toward an electronic patient record '97: proceedings. 1997:130-2. [pmcid: 420045].
DeVille K, Fitzpatrick J Ready or not, here it comes: the legal, ethical, and clinical implications of E-mail communications Sem Pediatr Surg 2000 9(1):24 34
di Biase N, Napoli A, Sabbatini A, et al Telemedicine in the treatment of diabetic pregnancy Ann Ist Super Sanita 1997 33(3):347 51 9542261
Dickinson G The Internet comes to Africa Can Med Assoc J 1999 160(3):
Dietel M, Nguyen-Dobinsky TN, Hufnagl P The UICC Telepathology Consultation Center. International Union Against Cancer. A global approach to improving consultation for pathologists in cancer diagnosis Cancer 2000 89(1):187 91 10897017
Dimmick SL, Mustaleski C, Burgiss SG, et al A case study of benefits and potential savings in rural home telemedicine Home Healthc Nurse 2000 18(2):125 135
Dionisio JD, Taira RK, Sinha U, et al Teleradiology as a foundation for an enterprise-wide health care delivery system Radiographics 2000 20(4):1137 50 10903702
Ditto S, Pille B Marketing on the Internet Healthc Exec 1998 13(5):54 5
Donnelly J Integrated communication cascade: better information, faster response Nurs Manage 2000 31(3):28 9 10827716
Doolittle GC A cost measurement study for a home-based telehospice service J Telemed Telecare 2000 6(Suppl 1):S193 5 10794017
Doughty K, Lewis R, McIntosh A The design of a practical and reliable fall detector for community and institutional telecare J Telemed Telecare 2000 6(Suppl 1):S150 4 10794003
Doze S, Simpson J, Hailey D, et al Evaluation of a telepsychiatry pilot project J Telemed Telecare 1999 5(1):38 46 10505368
Drake C Consumers are using the Internet to revolutionize health care AORN J 1999 70(6):1068 9 10635431
Droste TM Conflicting models put specialists and primary care physicians at odds Med Netw Strateg Rep 1997 6(1):1 3
Dublin AH Web-based technology: what every physician practice needs to know New Jersy Med 2000 97(8):51 5
Dunbar C Bill Gates eyes healthcare market Health Manage Technol 1995 16(2):24 6
Durr W A call center primer Healthc Inf Manage 1998 12(2):5 17 10182518
Durst L The Centre for Minimal Access Surgery-teaching for tomorrow J Telemed Telecare 2000 6(Suppl 2):S14 5 10975085
Dyer AM, Kirk AH A fully automated remote refraction system J Telemed Telecare 2000 6(Suppl 2):S16 8
Edwards G, Huang HK. Health care applications on California's communications superhighway. In: Proceedings of the. 1995;1995:71-85.
Edwards G, Sandberg L. The role of information technology in the evolution of health care delivery. In: HIMSS '97. The big picture: proceedings of the. 1997;1997:11-21.
Egger E Health care use of Internet faces both driving forces and barriers Health Care Strateg Manage 1999 17(10):19 20
Egglin TK, Feinstein AR Context bias. A problem in diagnostic radiology JAMA 1996 276(21):1752 5 8940325
Eid TA 1997: year of the "Internet backlash"? Healthcare Inform 1997 14(2):
Eikelboom RH, Yogesan K, Barry CJ, et al Methods and limits of digital image compression of retinal images for telemedicine Invest Ophthalmol Vis Sci 2000 41(7):1916 24 10845617
Elford R, White H, Bowering R, et al A randomized, controlled trial of child psychiatric assessments conducted using videoconferencing J Telemed Telecare 2000 6(2):73 82 10824374
Elfrink V, Martin K Educating for community nursing practice: point of care technology Healthc Inf Manage 1996 10(2):81 9 10157653
Eng TR, Maxfield A, Patrick K, et al Access to health information and support: a public highway or a private road? JAMA 1998 280(15):1371 5 9794322
Espinosa AL Availability of health data: requirements and solutions Int J Med Inform 1998 49(1):97 104 9723807
Eysenbach G, Diepgen TL [Internet: its significance in the prevention, delivery of health care and evidence-based medicine. Work Group Cybermedicine] Deutsche Medizinische Wochenschrift 1999 124(46):1404 5 10599258
Fabrizio MD, Lee BR, Chan DY, et al Effect of time delay on surgical performance during telesurgical manipulation J Endourol 2000 14(2):133 8 10772504
Falkenberry SS, Chung M, Legare R, et al The Breast Health Center at Women & Infants Hospital: origin, philosophy, and features Surg Oncol Clin North Am 2000 9(2):199 216
Fedele F, De Castro S, Volponi MC, et al The echocardiography laboratory in the informatic era Am J Cardiol 2000 86(4A):33G 35G
Fell D Customer centered health care: why managed care organizations must capitalize on new technology to build brands and customer loyalty Manage Care Q 1998 6(2):9 20
Ferguson T Self-care guru plugs information technology [interview by John McCormack] Health Data Manag 1997 5(11).
Ferry J Virtual doctors on the horizon in Seattle [news] Lancet 1999 354(9182):
Filip F, Mihalas G, Dimitriu R, et al. An approach to establishing a health information market. Stud Health Technol Inform. 1997;43:869-73. [pmid: 10179792].
Fink S, Gorden G. Healthcare and the Internet: using Internet technology to create competitive advantage. In: HIMSS '97. The big picture: proceedings of the 1997 Annual HIMMS Conference. 1997:199-214. [pmcid: 61235].
Finkelstein J, Cabrera MR, Hripcsak G Internet-based home asthma telemonitoring: can patients handle the technology? Chest 2000 117(1):148 55 10631213
Finkelstein J, Hripcsak G, Cabrera M Telematic system for monitoring of asthma severity in patients' homes MEDINFO 1998 9(Pt 1):272 6 10384460
Finkelstein J, Hripcsak G, Cabrera MR. Patients' acceptance of Internet-based home asthma telemonitoring. Proc AMIA Annual Symposium. 1998:336-40.
Finkelstein SM, Snyder M, Edin-Stibbe C, et al Monitoring progress after lung transplantation from home-patient adherence J Med Eng Technol 1996 20(6):203 10 9029392
Finley JP, Sharratt GP, Nanton MA, et al Paediatric echocardiography by telemedicine-nine years' experience J Telemed Telecare 1997 3(4):200 4 9614734
Firstenberg MS, Greenberg NL, Garcia MJ, et al Internet-based transfer of cardiac ultrasound images J Telemed Telecare 2000 6(3):168 71 10912336
Fischman J Drug bazaar: getting medicine off the Web is easy, but dangerous [news] US News World Rep 1999 126(24):58 62 10538325
Fitzgibbons R, Jr The reflections of an early innovator in the field of laparoscopic surgery JSLS: Soc Laparoendoscop Surg 2000 4(1):1 4
Fitzmaurice JM Health care data standards are required for medically effective use of workstations Int J Biomed Comput 1994 34(1-4):331 4 8125646
Flatley-Brennan P Computer network home care demonstration: a randomized trial in persons living with AIDS Comput Biol Med 1998 28(5):489 508 9861507
Florin D, Rosen R Evaluating NHS direct. Early findings raise questions about expanding the service [editorial] BMJ 1999 319(7201):5 6 10390433 1116148
Flory J If you build it, make sure they come: promoting your Web site Healthc Strat 1998 2(4):8 10
Flory J Patient and physician satisfaction is aim of new program Healthc Strat 1998 2(12).
Flower J Log on. A continuing guide to the online world for Healthc Execs, managers, clinicians & patients Healthc Forum J 1997 40(4):50 3 10169563
Flower J Log on. Technology decision-making Healthc Forum J 1997 40(5):38 41 10170361
Flower J Relationship tech Healthc Forum J 1999 42(5):14 7
Flower J The way it is, is not the way it will be Healthc Forum J 1999 42(4):16 22
Flower J, Dreifus LS, Bove AA, et al Technological advances and the next 50 years of cardiology J Am Coll Cardiol 2000 35(5 Suppl B):81B 90B
Fogliardi R, Frumento E, Rincon D, et al Telecardiology: results and perspectives of an operative experience J Telemed Telecare 2000 6(Suppl 1):S162 4 10794007
Formanek R, Jr Ophthalmology Hosp Pract 2000 35(5):
Fotheringham MJ, Owen N Introduction. Interactive Health Commun in preventive medicine Am J Prev Med 2000 19(2):111 2 10913901
Fotheringham MJ, Owies D, Leslie E, et al Interactive Health Commun in preventive medicine: internet-based strategies in teaching and research Am J Prev Med 2000 19(2):113 20
Fotsch E Finding opportunities in the chaotic online world Healthc Financ Manage 1996 50(7).
Fotsch E Medical Intranets create virtual healthcare malls Healthc Financ Manage 1998 52(1).
Fotsch E Meeting customer expectations for medical intranets Healthc Financ Manage 1998 52(9).
Fowler J, Martin G. The Healthcare Administrator's Associate: an experiment in distributed healthcare information systems. Proceedings AMIA Annual Fall Symposium. 1997:548-52.
France FH Ethics and biomedical information Int J Med Inform 1998 49(1):111 5 9723809
Frank S Does telesurgery fit in with the traditional Dutch legal framework? Med Law 2000 19(1):15 30 10876300
Frank SR Digital health care-the convergence of health care and the Internet J Ambul Care Manage 2000 23(2):8 17 10848396
Franke J MedBytes Texas Med 1999 95(9):
Frantz A Disease management-carpe diem home care Home Healthc Nurse 2000 18(1):15 7 11011639
Fraser HS, McGrath SJ Information technology and telemedicine in sub-saharan Africa [editorial] BMJ 2000 321(7259):465 6 10948012 1118376
Freedman SB Direct transmission of electrocardiograms to a mobile phone for management of a patient with acute myocardial infarction J Telemed Telecare 1999 5(1):67 9 10505372
Friedman BA Integrating laboratory processes into clinical processes, Web-based laboratory reporting, and the emergence of the virtual clinical laboratory Clin Lab Manage Rev 1998 12(5):333 8 10185012
Frost D, Beischer W Telemedicine in the management of pregnancy in type 1 diabetic women [letter] Diabetes Care 2000 23(6):863 4 10841015
Fujimoto M, Miyazaki K, von Tunzelmann N Complex systems in technology and policy: telemedicine and telecare in Japan J Telemed Telecare 2000 6(4):187 92 11027117
Furlow B Digital medical image management Radiol Technol 1999 70(5):434 45; quiz 446-8 10427588
Furness P, Rashbass J The virtual double-headedmicroscope: telepathology for all? [letter] Histopathology 2000 36(2):182 3 10733320
Gabler JM Shared information boosts competition in healthcare networks Comput Healthc 1993 14(3):20 3 10124402
Galfalvy HC, Reddy SM, Niewiadomska-Bugaj M, et al. Evaluation of Community Care Network (CCN) system in a rural health care setting. Proc Ann Symposium Comput App Med Care. 1995:698-702.
Game C Nursing-related information and data: what is the role of computers in nursing practice? Collegian 1996 3(3):20 2 9265492
Ganguly P, Ray P A methodology for the development of software agent based interoperable telemedicine systems: a tele-electrocardiography perspective Telemed J 2000 6(2):283 94 10957742
Garr DR, Lackland DT, Wilson DB Prevention education and evaluation in U. S. medical schools: a status report Acad Med 2000 75(7 Suppl):S14 21
Gates B Health ManageTechnol goes one on one with Bill Gates [interview] Health Manage Technol 1995 16(2):28 9
Gee PM The Internet. Part-II. A home care nursing clinical resource Home Healthc Nurse 1997 15(3):175 80 9110680
Gee PM The Internet-a home care nursing clinical resource: Part I Home Healthc Nurse 1997 15(2):115 21 9146152
Geehr EC Outcomes management. The search for what works Healthc Forum J 1992 35(4):28 33 10119521
Ghosh S Making business sense of the Internet Harvard Bus Rev 1998 76(2):126 35
Giannantonio F Automated accounts receivable management with EDI Caring 1993 12(7):42 5 10127007
Gilbert JA Beyond billboards: building interactive Web sites Health Data Manag 1998 6(12):40 4 10187488
Gilbert JA Disease management hits home Health Data Manag 1998 6(8):54 6 10181949
Gilbert JA Patient education in the computer age Health Data Manag 1998 6(5):94 7 10180316
Gilbert JA Special report. Outcomes Health Data Manag 1998 6(4):66 7 10179385
Gillespie G But are they satisfied? Technology enables organizations to get faster and more accurate results from patient satisfaction surveys Health Data Manag 1999 7(5):90 2 10387708
Gillespie G You've got mail? So do your patients Health Data Manag 1999 7(7):82 4 10539182
Gillespie K Is there a doctor in the house? New Jersy Med 1997 94(4):45 9
Gilmour E, Campbell SM, Loane MA, et al Comparison of teleconsultations and face-to-face consultations: preliminary results of a United Kingdom multicentre teledermatology study Br J Dermatol 1998 139(1):81 7 9764153
Glaessl A, Schiffner R, Walther T, et al Teledermatology-the requirements of dermatologists in private practice J Telemed Telecare 2000 6(3):138 41 10912330
Gogh A The impact of information technology Caring 1997 16(12):74 6 10176260
Gold M, Siegel J, Russell L, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Goldberg B. Supporting shared healthcare delivery using Intranet technologies. InStudies of patient satisfaction with telemedicine are inconclusive. BMJ. 2000;320(June 3):G. patient record '97: proceedings. 1997:225-30.
Golder DT, Brennan KA Practicing dentistry in the age of telemedicine J Am Dent Assoc 2000 131(6):734 44 10860325
Goldmeier D, Ivens D Distant healing [letter; comment] Int J STD AIDS 2000 11(3):
Goldsmith DM, Safran C. Using the Web to reduce postoperative pain following ambulatory surgery. Proceedings AMIA Annual Symposium. 1999:780-4.
Goldsmith J How will the Internet change our health system? Health Aff 2000 19(1):148 56
Goldsmith JC A new industrial order for physicians: a talk with Jeff C. Goldsmith, PhD [interview by Richard L. Reece] Phys Exec 2000 26(1):16 9
Goldstein D Extranets: innovative on-line health care alliances Manag Care Interface 1997 10(11):50 2
Goldstein D, Flory J Health care systems reach out over the Internet: Part II Med Interface 1997 10(7):62 4 10169973
Goldstein D, Flory J The Internet revolution: transforming health care delivery Med Interface 1997 10(2):56 8
Goldstein D, Toth C E-consumers and e-commerce challenge traditional referral patterns Manag Care Interface 1999 12(8):44 6
Gottlieb S Study explores internet as a tool for care of diabetic patients [news] West J Med 2000 173(1):8 9 10903273
Gotwald TF, Daniaux M, Stoeger A, et al The value of the World Wide Web for tele-education in radiology J Telemed Telecare 2000 6(1):27 30 10824387
Graham LE, McGimpsey S, Wright S, et al Could a low-cost audio-visual link be useful in rheumatology? J Telemed Telecare 2000 6(Suppl 1):S35 7
Graschew G, Rakowsky S, Balanou P, et al Interactive telemedicine in the operating theatre of the future J Telemed Telecare 2000 6(Suppl 2):S20 4
Gray J, Brain K, Iredale R, et al A pilot study of telegenetics [letter] J Telemed Telecare 2000 6(4):245 7 11027129
Gray J, Pompilio-Weitzner G, Jones PC, et al. Videoconferencing and Internet communication between the NICU and patient homes. In: HIMSS '99. Discover the synergy. 1999:153-62. [pmcid: 103544].
Gray J, Pompilio-Weitzner G, Jones PC, et al. Baby CareLink: development and implementation of a WWW-based system for neonatal home telemedicine. Proceedings AMIA Annual Symposium. 1998:351-5.
Gray JE, Safran C, Davis RB, et al Baby care link: Using the Internet and telemedicine to improve care for high-risk infants Pediatrics 2000 106(6):1318 1324 11099583
Green M, White L The Cave-let: a low-cost projective immersive display J Telemed Telecare 2000 6(Suppl 2):S24 6 10975089
Greenberg EA, Ismeurt R, Long CO, et al An Internet primer. Part I Home Healthc Nurse 1999 17(8):497 502; quiz 503 10745773
Greenberg EA, Ismeurt R, Long CO, et al Searching the Web Home Healthc Nurse 1999 17(9):581 5; quiz 586 10763656
Greenberg EA, Long CO, Ismeurt R, et al What the Internet can do for you. Focus: continuing education Home Healthc Nurse Manager 1999 3(6):8 13
Griffith H Internet magic Journal of Professional Nursing 1996 12(1):
Grimm CB Healthcare computing: achieving mobility Healthcare Inform 1996 13(1):52 4
Grimm CB Home healthcare on the move Healthcare Inform 1995 12(9).
Grimm CB Wireless and mobile: moving ahead Healthcare Inform 1996 13(11).
Grove AS A piece of my mind. The X Factor JAMA 1998 280(15):
Gul YA, Wan AC, Darzi A Undergraduate surgical teaching utilizing telemedicine Med Educ 1999 33(8):596 9 10447846
Gulube S, Wynchank S Telemedicine-redressing South Africa's health care imbalance [editorial] [see comments] South Afr Med J 1999 89(6):623 4
Gumprecht T Are we all just stupid? Ear Nose Throat J 2000 79(9):
Gunn IP Commentary: issues and perspectives affecting CRNA practice. Regulation of health professionals, Part 1: Telepractice CRNA 1999 10(2):86 92 10504915
Gurney J Computers in thoracic radiology J Thor Imaging 2000 15(2):136 7
Gustafson DH, Boberg E, Bricker E, et al. Using of quality management to develop and test a computer-based system to help AIDS patients improve their quality of life and reduce costs of care [abstract]. AHSR FHSR Ann Meeting Abstract Book. 1994;11.
Gustafson DH, Hawkins R, Boberg E, et al Impact of a patient-centered, computer-based health information/support system Am J Prev Med 1999 16(1):1 9
Gustafson DH, Robinson TN, Ansley D, et al Consumers and evaluation of interactive Health Commun applications. The Science Panel on Interactive Communication and Health Am J Prev Med 1999 16(1):23 9
Hagland M How "WebCare" is changing health care delivery, hit by hit Health Manage Technol 1997 18(4):22 3
Hakansson S, Gavelin C What do we really know about the cost-effectiveness of telemedicine? J Telemed Telecare 2000 6(Suppl 1):S133 6 10793998
Hammond WE The status of healthcare standards in the United States Int J Biomed Comput 1995 39(1):87 92 7601547
Handysides S Keeping the customer satisfied [editorial] Commun Dis Pub Health 1998 1(2):77 8 9644117
Hardin WD, Jr Clinical information systems Sem Pediatr Surg 2000 9(1):35 9
Haroske G, Meyer W, Oberholzer M, et al Competence on demand in DNA image cytometry Pathol Res Pract 2000 196(5):285 91 10834384
Harper DM, Moncur MM, Harper WH, et al The technical performance and clinical feasibility of telecolposcopy J Fam Pract 2000 49(7):623 7 10923572
Harris G The new telecare: emerging Internet-based models for home healthcare Telemed Today 1999 7(4):15 6 10623392
Harrison PV, Kirby B, Dickinson Y, et al Teledermatology-high technology or not? J Telemed Telecare 1998 4(Suppl 1):31 2 9640726
Haslam R, McLaren P Interactive television for an urban adult mental health service: the Guy's Psychiatric Intensive Care Unit Telepsychiatry Project J Telemed Telecare 2000 6(Suppl 1):S50 2
Hatem MB Integrating clinical engineering and information systems Biomed Instrum Technol 1999 33(4):295 7 10459412
Haugh R The new consumer Hosp Health Netw 1999 73(12):30 4, 36 10633773
Haugh R, Kelly J, Sarudi D, et al From promises to performance: a look at four innovative technology packages that might revolutionize health care Hosp Health Netw 2000 74(7):38 42, 44, 46 passim
Haughom JL Transforming U. S. health care: the arduous road to value Top Health Inf Manage 2000 20(3):1 10 10747429
Haukipuro K, Ohinmaa A, Winblad I, et al The feasibility of telemedicine for orthopaedic outpatient clinics-a randomized controlled trial J Telemed Telecare 2000 6(4):193 8 11027118
Hawker F, Kavanagh S, Yellowlees P, et al Telepsychiatry in South Australia J Telemed Telecare 1998 4(4):187 94 10505352
Hayward T, Mitchell J The cost-effectiveness of teleradiology at the Women's and Children's Hospital in Adelaide J Telemed Telecare 2000 6(Suppl 1):S23 5 10793962
Hayward T, Mitchell J Teleradiology at the tertiary-level Women's and Children's Hospital in South Australia Telemed J 2000 6(2):205 11 10957732
Hazy T, French JF, Lester J. How useful is the Internet for facilitating the delivery of care under capitation?. Infocare. p 1996:Mar-Apr.
Heautot JF, Eichelberg M, Gibaud B, et al The RETAIN project: DICOM teleradiology over an ATM-based network. Radiological Examinations Transfer on an ATM Integrated Network Eur Radiol 2000 10(1):175 82 10663740
Heimoff S The irrepressible computer. The brave new world of healthcare information technology Healthc Forum J 1998 41(1):14 9 10175819
Helwig AL, Lovelle A, Guse CE, et al An office-based Internet patient education system: a pilot study J Fam Pract 1999 48(2):123 7 10037543
Henderson I, vanLohuizen K, Fenske T Remote cardiac rehabilitation J Telemed Telecare 2000 6(Suppl 2):S28 30 10975091
Heneghan C, Sclafani AP, Stern J, et al Telemedicine applications in otolaryngology IEEE Eng Med Biol Mag 1999 18(4):53 62
Henry LA What the hospitalist movement means to family physicians Fam Pract Manage 1998 5(10):54 62
Hernando ME, Gomez EJ, Corcoy R, et al Evaluation of DIABNET, a decision support system for therapy planning in gestational diabetes Comput Methods Programs Biomed 2000 62(3):235 48 10837909
Herrmann D, Bryant M How technology can make you a hero with your customers Healthc Inf Manage 1998 12(2):59 69
Hersh WR, Wallace JA, Patterson PK, et al. Telemedicine for the medicare population. Evidence Report/Technology Assessment No. 24 (prepared by the Oregon Health Sciences University Evidence-based Practice Center under Contract No. 290-97-0018). AHRQ Publication No. 01-E012. Rockville, MD: Agency for Healthcare Research and Quality.; 2001, in press.
Herxheimer A, McPherson A, Miller R, et al Database of patients' experiences (DIPEx): a multi-media approach to sharing experiences and information Lancet 2000 355(9214):1540 3 10801187
Herzlinger R The health care consumer gospel according to Harvard Business School: a talk with Regina Herzlinger, DBA [interview by Richard L. Reece] Phys Exec 2000 26(3):36 40
Hickey ME The age of the Internet: working through the grief cycle (again) Phys Exec 2000 26(1):Jan Feb
Hickey P AORN's role in the Best Practice Network AORN J 2000 71(3):664 70 10836936
Hicks LL, Boles KE, Hudson ST, et al An evaluation of satisfaction with telemedicine among health-care professionals J Telemed Telecare 2000 6(4):209 15 11027121
High WA, Houston MS, Calobrisi SD, et al Assessment of the accuracy of low-cost store-and-forward teledermatology consultation J Am Acad Dermatol 2000 42(5 Pt 1):776 83 10775853
Hilsden RJ, Meddings JB, Verhoef MJ Complementary and alternative medicine use by patients with inflammatory bowel disease: An Internet survey Can J Gastroenterol 1999 13(4):327 32 10360993
Hilty DM, Nesbitt TS, Canning RD, et al Telepsychiatry for the management of a liver transplantation candidate in the primary care setting [letter] Gen Hosp Psychiatry 2000 22(2):122 3 10896490
Hilty DM, Sison JI, Nesbitt TS, et al Telepsychiatric consultation for ADHD in the primary care setting [letter] J Am Acad Child Adolesc Psychiatry 2000 39(1):15 6 10638062
Hjelm NM, Hazlett CB Theory of telemedicine: the expressivity of the virtual patient [letter] J Telemed Telecare 2000 6(2):119 20 10824381
Hoban L Humanizing voice mail in healthcare J Nurs Admin 1999 29(2):50 6
Holland JF New medicine for the new millennium Mt Sinai J Med 1999 66(1):35 6 9989104
Hollingsworth B Health Econ e-mail discussion lists Health Econ 1997 6(1):95 7 9142536
Holtan A Patient reactions to specialist telemedicine consultations-a sociological approach J Telemed Telecare 1998 4(4):206 13 10505356
Horton R North and South: bridging the information gap Lancet 2000 355(9222):2231 6 10881907
Horton R North and South: bridging the information gap Lancet 2000 355(9222):2231 6 10881907
Hough B Formative evaluation of a World Wide Web-based Chiari malformation hypermedia program J Biocomunic 1997 24(4):22 32
Houghton PE, Kincaid CB, Campbell KE, et al Photographic assessment of the appearance of chronic pressure and leg ulcers Ostomy Wound Manage 2000 46(4):20 6, 28-30 10788924
Hovenga EJ, Hovel J, Klotz J, et al Infrastructure for reaching disadvantaged consumers: telecommunications in rural and remote nursing in Australia J Am Med Inform Assoc 1998 5(3):269 75 61301 9609497
Hovey JV Unleashing the potential. Powerful changes are afoot as health plans use Internet technology for customer service Healthplan 1997 38(3):40 7 10176863
Hripcsak G, Knirsch CA, Jain NL, et al A health information network for managing innercity tuberculosis: bridging clinical care, public health, and home care Comput Biomed Res 1999 32(1):67 76 10066356
Hu B, Bai J, Ye D A telemedicine management model based on message-trigger service Methods Inf Med 2000 39(1):73 7 10786074
Huang MP, Alessi NE Challenges of the World Wide Web Pyschiatr Ser 1999 50(4):483 4, 491
Huckman MS Singing out of our range [editorial] AJNR Am J Neuroradiol 1996 17(8):
Hudson T Be on the lookout Hosp Health Netw 1999 73(4):56 8, 60 10224970
Huh SJ, Shirato H, Hashimoto S, et al An integrated service digital network (ISDN)-based international telecommunication between Samsung Medical Center and Hokkaido University using telecommunication helped radiotherapy planning and information system (THERAPIS) Radiother Oncol 2000 56(1):121 3 10869763
Humphreys BL, Hole WT, McCray AT, et al Planned NLM/AHCPR large-scale vocabulary test: using UMLS technology to determine the extent to which controlled vocabularies cover terminology needed for health care and public health J Am Med Inform Assoc 1996 3(4):281 7 116311 8816351
Hunkeler EM, Meresman JF, Hargreaves WA, et al Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care [comment] Arch Fam Med 2000 9(8):700 8 10927707
Hwang S, Lee J, Kim H, et al Development of a web-based picture archiving and communication system using satellite data communication J Telemed Telecare 2000 6(2):91 6 10824376
Hyer RN Telemedical experiences at an Antarctic station J Telemed Telecare 1999 5(Suppl 1):S87 9 10534856
Iglehart J Forum on the future of academic medicine: final session-implications of the information revolution for academic medicine Acad Med 2000 75(3):245 51 10724312
Impicciatore P, Pandolfini C, Casella N, et al Reliability of health information for the public on the World Wide Web: systematic survey of advice on managing fever in children at home BMJ 1997 314(7098):1875 9 9224132
Infiorati ME Grappling with information-sharing strategies Caring 1995 14(8):88 91 10151226
Iserson KV Telemedicine: a proposal for an ethical code Cambridge Q Healthc Ethics 2000 9(3):404 6
Jackson JR The urgent call for knowledge management in medicine Phys Exec 2000 26(1):28 31
Jackson R Information systems on the Internet: time to make the move Health Sys Leader 1997 4(5):23 6
Jacobs P, Hall E, Henderson I, et al Episodic acute care costs: linking inpatient and home care Can J Public Health 1995 86(3):200 5 7671208
Jacobsen TJ Workstations as enabling technologies for the computer-based patient record (CPR): point of care approaches across the patient care continuum-nursing's perspective Int J Biomed Comput 1994 34(1-4):123 9 8125624
Jahn M Laboratory information systems, Part 2. How well does LIS reach all 4 corners of the lab? MLO Med Lab Obs 1996 28(1):53 7 10154376
Jaklevic MC Healthcare Web surfers get guides [news] Mod Healthc 1996 26(14):
Jardine I, Clough K, Navein J The potential for telemedicine and telecare in Deptford J Telemed Telecare 2000 6(Suppl 1):S77 9 10793980
Jean FC, Lavril M, Lemaitre D, et al A software engineering approach for medical workstations development Int J Biomed Comput 1994 34(1-4):249 60 8125636
Jenkins J. Providing a personalised health information service to people's homes. In: Toward an electronic patient record '97: proceedings. 1997:231-5. [pmcid: 158298].
Jennett P, Nijssen-Jordan C, Wiggs B, et al Telelearning in a partnership between a university faculty and a regional health authority: benefits, challenges and strategies J Telemed Telecare 2000 6(Suppl 2):S32 5
Jerant AF Home telemedicine: merging the old and new ways [editorial; comment] Am Fam Physician 1999 60(4):
Jerome LW, DeLeon PH, James LC, et al The coming of age of telecommunications in psychological research and practice Am Psychol 2000 55(4):407 21 10812693
Jin C, Ishikawa A, Sengoku Y, et al A telehealth project for supporting an isolated physiotherapist in a rural community of Hokkaido J Telemed Telecare 2000 6(Suppl 2):S35 7
Johnshoy-Currie CJ Behavioral health tomorrow. Stepping up to the challenge MD Comput 2000 17(1):19 21 10710928
Johnson DE Internet serving inquiring patients. Web powerful resource for health care providers, insurers Profiles in Healthcare Marketing 1998 14(3):23 6 10179503
Johnson DI Using external data and databases: issues and sources Journal of Nursing Care Quality 1995 10(1):31 9 7579545
Johnson JA, Coons SJ, Hays RD, et al Health status and satisfaction with pharmacy services Am J Manag Care 1999 5(2):163 70 10346512
Johnston B, Wheeler L, Deuser J, et al Outcomes of the Kaiser Permanente Tele-Home Health Research Project Arch Fam Med 2000 9(1):40 5 10664641
Jones CM The Internet access breakthrough. Bringing healthcare home Healthcare Inform 1997 14(7).
Jones DJ e-health: will we be victims once again? [editorial] Am J Med Qual 2000 15(3):83 4 10872257
Jones MG Perspectives. Use of telemedicine for home care ripe for experiment Med Health 1998 52(43):1 4 10186055
Jones PC, Silverman BG, Athanasoulis M, et al. Nationwide telecare for diabetics: a pilot implementation of the HOLON architecture. Proc AMIA Ann Symposium. 1998:346-50.
Jones RW, Clarke M, Kanellopoulos N, et al The AIDMAN project-a telemedicine approach to cardiology investigation, referral and outpatient care J Telemed Telecare 2000 6(Suppl 1):S32 4
Jonsson PM, Ostman J, Carlsson C, et al [Patients with diabetes search facts about their disease on the net. More information in Swedish is needed] Lakartidningen 1999 96(24):2970 4 10402805
Jukic DM, Bifulco CB Telepathology and pathology at distance: an overview Croatian Med J 1999 40(3):421 4
Kaczorowski R Connected care. The Andover Working Group Hosp Q 1998 1(3):49 52 10345581
Kaihara S Workstation network system which enables international exchange of characters and images at the University of Tokyo Hospital Int J Biomed Comput 1994 34(1-4):357 61 8125650
Kaiser F Maximizing Internet access Mich Health Hosp 1998 34(5):Sep Oct
Kalfoglou AL, Gittelsohn J A qualitative follow-up study of women's experiences with oocyte donation Hum Reprod 2000 15(4):798 805 10739823
Kangarloo H, Valdez JA, Yao L, et al Improving the quality of care through routine teleradiology consultation Acad Radiol 2000 7(3):149 55 10730809
Karlsson D, Ekdahl C, Wigertz O, et al. A qualitative study of clinicians ways of using a decision-support system. Proc AMIA Ann Fall Symposium. 1997:268-72.
Karlsten R, Sjoqvist BA Telemedicine and decision support in emergency ambulances in Uppsala J Telemed Telecare 2000 6(1):1 7 10824383
Karp WB, Grigsby RK, McSwiggan-Hardin M, et al Use of telemedicine for children with special health care needs Pediatrics 2000 105(4 Pt 1):843 7 10742330
Kasalova H, Mellanova A. Keeping the elderly at home. Stud Health Technol Inform. 1998;48:258-60. [pmid: 10186523].
Kassirer JP The next transformation in the delivery of health care [editorial] New Eng J Med 1995 332(1):52 4 7990866
Katayama T, Mikasa H, Hisashige A. Development of a decision making system on the internet for treatment of an early-stage breast cancer [abstract]. Ann Meeting Int Soc Technol Assess Health Care. 14.
Kato K, Shimamoto K, Ishigaki T, et al An experimental teleradiology transmission system using a high-speed ATM backbone network J Telemed Telecare 2000 6(2):114 8 10824380
Katon W Improvement of outcomes in chronic illness [comment] [editorial] Arch Fam Med 2000 9(8):709 11 10927708
Keener RE Has consultants' spigot slowed as providers ponder waste? Health Manage Technol 2000 21(1):10 2
Kelly K The structure of organized change [interview by Joe Flower] Healthc Forum J 1995 38(1):34 41 10154287
Kennedy C The Internet in managed health care Manage Care Q 1998 6(1):23 8
Kennedy C, Yellowlees P A community-based approach to evaluation of health outcomes and costs for telepsychiatry in a rural population: preliminary results J Telemed Telecare 2000 6(Suppl 1):S155 7 10794004
Kennedy M A tool for patient education Health Data Manag 1996 4(2).
Kennedy RH Partnering through telemedicine to improve the quality of health-care J Telemed Telecare 2000 6(Suppl 1):S137 9 10793999
Kenny C, Steele K E-mail consultations [letter] Br J Gen Pract 2000 50(455):503 4
Kertesz L What does it all mean? Making sense of health plan data Mod Healthc 1998 28(16):98 106 10179152
Khandheria BK, Gilbert BK, Hattery RR, et al. Role of the national information infrastructure on health care delivery in a resource-constrained environment. In: Health care technology policy. 1994;1994:192-5.
Khorasani R, Goldhaber SZ Imaging. Improving healthcare delivery Lancet 1998 352(Suppl 4):
Kiel JM Homecare online: a new twist on house calls MD Comput 1999 16(4):21 2 10507231
King J Electronic referrals: increasing satisfaction, reducing costs Infocare p 1996 16(18):May Jun
Kingsnorth A, Vranch A, Campbell J Training for surgeons using digital satellite television and videoconferencing J Telemed Telecare 2000 6(Suppl 1):S29 31 10793964
Kinsella A Home telecare in the United States J Telemed Telecare 1998 4(4):195 200 10505353
Kirkwood KT, Peck DF, Bennie L The consistency of neuropsychological assessments performed via telecommunication and face to face J Telemed Telecare 2000 6(3):147 51 10912332
Klint RB Emerging from the cybermaze Phys Exec 2000 26(1):Jan Feb
Knox D, Mischke L Implementing a congestive heart failure disease management program to decrease length of stay and cost J Cardiovasc Nurs 1999 14(1):55 74 10533692
Kofos D, Pitetti R, Orr R, et al Telemedicine in pediatric transport: a feasibility study Pediatrics 1998 102(5):
Kolesar MS Realizing the competitive advantage of the Internet Caring 1997 16(12):56 8 10176258
Kolitsi Z, Iakovidis I Improving user acceptance of health-care telematics J Telemed Telecare 2000 6(Suppl 2):S37 9 10975095
Kooijman CJ, Kaag ME Sending specialist reports to GPs using EDI MEDINFO 1998 9(Pt 1):408 11 10384488
Korpman RA Integrating home health care into your information technology strategy Health Care Innov 1998 8(2):20 3 10178341
Korpman RA Integrating home health care into your IT strategy: electronic communications maximize the benefits of providing care beyond your inpatient facilities NAHAM Manage J 1998 24(4).
Kozma CM The role of the Internet in patient empowerment Manag Care Interface 1999 12(3):73 4 10351411
Kratz LA, Augustine H, Fitzmaurice JM, et al. The National Information Infrastructure: reengineering health care on a national basis. In: Proceedings of the Annual MIMMS Conference. 1995;1995:25-38.
Kremsdorf R, Regan DW Delivering first-class healthcare in today's environment means giving physicians easy access to computer-based patient information Healthc Exec 1997 12(2):41 2
Krishna S, Balas EA, Spencer DC, et al Clinical trials of interactive computerized patient education: implications for family practice J Fam Pract 1997 45(1):25 33 9228910
Kroeker KI, Diamond R, Jennett PA, et al Video-capture teleradiology for the after-hours reading of computerized tomography scans J Telemed Telecare 2000 6(4):229 32 11027125
Kronz JD, Silberman MA, Allsbrook WC, Jr., et al Pathology residents' use of a Web-based tutorial to improve Gleason grading of prostate carcinoma on needle biopsies Hum Pathol 2000 31(9):1044 50 11014569
Krupinski EA, LeSueur B, Ellsworth L, et al Diagnostic accuracy and image quality using a digital camera for teledermatology Telemed J 1999 5(3):257 63 10908439
Kully D Telehealth in speech pathology: applications to the treatment of stuttering J Telemed Telecare 2000 6(Suppl 2):S39 41 10975096
Kuszler PC Telemedicine and integrated health care delivery: compounding malpractice liability Am J Law Med 1999 25(2-3):297 326 10476332
Kvedar JC, Menn ER, Baradagunta S, et al Teledermatology in a capitated delivery system using distributed information architecture: design and development Telemed J 1999 5(4):357 66 10908451
Labkoff SE, Shah S, Bormel J, et al. The Constellation Project: experience and evaluation of personal digital assistants in the clinical environment. Proc Ann Symposium Comput App Med Care. 1995:678-82.
Ladd JD, Reese RG Traveling the information superhighway Mich Hosp 1994 30(2):40 5 10134214
Lahdenpera TS, Kyngas HA Patients' views about information technology in the treatment of hypertension J Telemed Telecare 2000 6(2):108 13 10824379
Lamminen H, Salminen L, Uusitalo H Teleconsultations between general practitioners and ophthalmologists in Finland J Telemed Telecare 1999 5(2):118 21 10628022
Lange A, van de Ven JP, Schrieken BA, et al Internet-mediated, protocol-driven treatment of psychological dysfunction J Telemed Telecare 2000 6(1):15 21 10824385
Lange T, Indelicato DJ, Rosen JM Virtual reality in surgical training Surg Oncol Clin North Am 2000 9(1):61 79, vii
Laniado ME, Feneley MR Urologists on the Internet: practical applications are now a reality Br J Urol 1997 80(Suppl 3):12 5 9415078
Lapostolle F, Desmaizieres M, Adnet F, et al Telephone-assisted Heimlich maneuver [letter] Ann Emerg Med 2000 36(2):
Lattimore MR, Jr A store-forward ophthalmic telemedicine case report from deployed U. S. Army forces in Kuwait Telemed J 1999 5(3):309 13 10908445
Laughlin ML Telecommunications may offer poor a 'road' to healthcare Comput Healthc 1992 13(11):32 3 10122901
Lavelle FW Looking ahead to the year 2010: future applications of the electronic information highway J AHIMA 1994 65(8):44 6 10135559
Laxton CE Infection control. An idea whose time has come Caring 1996 15(7):13 4
LeBlanc A Louisiana Rural Health Access Program J Louisiana State Med Soc 2000 152(2):89 93
Lee CV, Irving JL Sources of spatial data for community health planning J Public Health Manage Pract 1999 5(4):7 22
Lee JH, Kim JH, Jhoo JH, et al A telemedicine system as a care modality for dementia patients in Korea Alzheimer Dis Assoc Disord 2000 14(2):94 101 10850748
Lee MS, Shin DS, Berger JW Grading, image analysis, and stereopsis of digitally compressed fundus images Retina 2000 20(3):275 81 10872933
Lee RG, Chen HS, Lin CC, et al Home telecare system using cable television plants-an experimental field trial IEEE Trans Inf Technol Biomed 2000 4(1):37 44 10761772
Lee SK, Peng CH, Wen CH, et al Consulting with radiologists outside the hospital by using Java Radiographics 1999 19(4):1069 75 10464809
Lee SY, Frankel HL Ultrasound and other imaging technologies in the intensive care unit Surg Clin North Am 2000 80(3):975 1003 10897274
Lehoux P, Battista RN, Lance JM Telehealth: passing fad or lasting benefits? Can J Public Health 2000 91(4):277 80 10986786
Lemaire ED, Boudrias Y, Greene G Technical evaluation of a low-bandwidth, Internet-based system for teleconsultations J Telemed Telecare 2000 6(3):163 7 10912335
Lenert LA, Cher DJ Use of meta-analytic results to facilitate shared decision making J Am Med Inform Assoc 1999 6(5):412 9 61383 10495100
Leong AS, Visinoni F, Visinoni C, et al An advanced digital image-capture computer system for gross specimens: a substitute for gross description Pathology 2000 32(2):131 5 10840835
Letterie GS, Morgenstern LL, Johnson L The role of an electronic mail system in the educational strategies of a residency in obstetrics and gynecology Obstet Gynecol 1994 84(1):137 9 8008309
Levy BA TSBME does regulate [letter] Texas Med 2000 96(8):9 10
Lewis K, Gilmour E, Harrison PV, et al Digital teledermatology for skin tumours: a preliminary assessment using a receiver operating characteristics (ROC) analysis J Telemed Telecare 1999 5(Suppl 1):S57 8 10534843
Lewis L, Walters A, Griffith A Managing pre-examination stress through remote counselling using a session script from a 'sentinel subject' J Telemed Telecare 2000 6(Suppl 2):S43 4
Ley JL. Balancing quality and productivity in the desktop services environment. In: HIMSS '99. Discover the synergy: proceedings of the. 1999;1999:321-30.
Li HK, Tang RA, Oschner K, et al Telemedicine screening of glaucoma Telemed J 1999 5(3):283 90 10908442
Liesenfeld B, Kohner E, Piehlmeier W, et al A telemedical approach to the screening of diabetic retinopathy: digital fundus photography Diabetes Care 2000 23(3):345 8 10868863
Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnostic tests JAMA 1999 282(11):1061 6 10493205
Lilford RJ, Braunholtz DA, Greenhalgh R, et al Trials and fast changing technologies: the case for tracker studies BMJ 2000 320(7226):43 6 10617532 1117318
Lim AC, Egerton IB, Shumack SP Australian teledermatology: the patient, the doctor and their government Aust J Dermatol 2000 41(1):8 13
Lin JC Applying telecommunication technology to health-care delivery IEEE Eng Med Biol Mag 1999 18(4):28 31 10429899
Lin JC Current developments in telemedicine [editorial] IEEE Eng Med Biol Mag 1999 18(4):
Lincoln TL, Builder C Global healthcare and the flux of technology Int J Med Inform 1999 53(2-3):213 24 10193890
Lincoln TL, Builder C Global healthcare and the flux of technology MEDINFO 1998 9(Pt 2):1213 7 10384653
Lindberg CC Implementation of in-home telemedicine in rural kansas: answering an elderly patient's needs J Am Med Inform Assoc 1997 4(1):14 7 61193 8988469
Lindberg DA, Humphreys BL High-performance computing and communications and the national information infrastructure: new opportunities and challenges [editorial] J Am Med Inform Assoc 1995 2(3):116273
Liu L, Miyazaki M Telerehabilitation at the University of Alberta J Telemed Telecare 2000 6(Suppl 2):S47 9 10975100
Loane MA, Bloomer SE, Corbett R, et al Patient satisfaction with realtime teledermatology in Northern Ireland J Telemed Telecare 1998 4(1):36 40
Loane MA, Bloomer SE, Corbett R, et al A randomized controlled trial to assess the clinical effectiveness of both realtime and store-and-forward teledermatology compared with conventional care J Telemed Telecare 2000 6(Suppl 1):S1 3 10793956
Loane MA, Corbett R, Bloomer SE, et al Diagnostic accuracy and clinical management by realtime teledermatology. Results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial J Telemed Telecare 1998 4(2):95 100
Loane MA, Gore HE, Corbett R, et al Effect of camera performance on diagnostic accuracy: preliminary results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial J Telemed Telecare 1997 3(2):83 8 9206278
Lobach DF. Electronically distributed, computer-generated, individualized feedback enhances the use of a computerized practice guideline. Proc AMIA Ann Fall Symposium. 1996:493-7.
Lobach DF, Spell RU, Hales JW, et al. A Web link management tool for optimizing utilization of distributed knowledge in health care applications. ProcAMIA Ann Symposium. 1999:839-43.
Logan GD, Radcliffe DF Supporting communication in rehabilitation engineering teams Telemed J 2000 6(2):225 36 10957735
Lou SL, Lin HD, Lin KP, et al Automatic breast region extraction from digital mammograms for PACS and telemammography applications Comput Med Imaging Graphics 2000 24(4):205 20
Lugo-Vicente H Internet resources and web pages for pediatric surgeons Sem Pediatr Surg 2000 9(1):11 8
Lyon CC, Harrison PV A portable digital imaging system in dermatology: diagnostic and educational applications J Telemed Telecare 1997 3(Suppl 1):81 3 9218395
O'Reilly M Health care begins to merge with the information highway Can Med Assoc J 1994 151(8):1173 6 7922950 1337247
O'Reilly M Is Internet-based disease management on the way? Can Med Assoc J 1999 160(7):
Maass M, Kosonen M, Kormano M Transportation savings and medical benefits of a teleneuroradiological network J Telemed Telecare 2000 6(3):142 6 10912331
Macedonia CR, Littlefield RJ, Coleman J, et al Three-dimensional ultrasonographic telepresence J Telemed Telecare 1998 4(4):224 30 10505359
Macomber LT, Sadler GR. Cancer information highway: enhancing patient/staff education using the Internet. In: HIMSS '97. The big picture: proceedings of the. 1997;1997:345-59.
MacStravic S Adding value via the Internet Healthc Exec 1999 14(2):Mar Apr
MacStravic S The downside of patient empowerment Healthc Forum J 2000 43(1):30 1
Madigan EA Evidence-based practice in home healthcare. A springboard for discussion Home Healthc Nurse 1998 16(6):411 5 9708155
Magnusson L Carers tap into the information highway Nurs Times 1999 95(42):48 50 10788888
Main ML, Foltz D, Firstenberg MS, et al Real-time transmission of full-motion echocardiography over a high-speed data network: impact of data rate and network quality of service J Am Soc Echocardiograph 2000 13(8):764 70
Mair F, Whitten P Systematic review of studies of patient satisfaction with telemedicine BMJ 2000 320(7248):1517 20 27397 10834899
Mair F, Whitten P, May C, et al Patients' perceptions of a telemedicine specialty clinic J Telemed Telecare 2000 6(1):36 40 10824389
Mair FS, Haycox A, May C, et al A review of telemedicine cost-effectiveness studies J Telemed Telecare 2000 6(Suppl 1):S38 40 10793967
Mair FS, Wilkinson M, Bonnar SA, et al The role of telecare in the management of exacerbations of chronic obstructive pulmonary disease in the home J Telemed Telecare 1999 5(Suppl 1):S66 7 10534847
Maki RH, Maki WS, Patterson M, et al Evaluation of a Web-based introductory psychology course: I. Learning and satisfaction in on-line versus lecture courses Behav Res Methods Instrume Comput 2000 32(2):230 9
Mandil SH Telematics in health care in developing countries J Med Syst 1995 19(2):195 203 7602252
Mandl KD, Kohane IS, Brandt AM Electronic patient-physician communication: problems and promise Ann Intern Med 1998 129(6):495 500 9735088
Mangan D Save time and please patients with e-mail Med Econ 1999 76(13):155 6 10539325
Marrero DG, Vandagriff JL, Kronz K, et al Using telecommunication technology to manage children with diabetes: the Computer-Linked Outpatient Clinic (CLOC) Study Diabetes Educ 1995 21(4):313 9 7621734
Martin ER Consumer health informatics: the medical librarian's role J AHIMA 1998 69(8):38 40 10182505
Martin ER, Lanier D Networking consumer health information: bringing the patient into the medical information loop Bull Med Libr Assoc 1996 84(2):240 6 299417 8826631
Masero V, Sanchez FM, Uson J An integrated system of telemedicine for minimally invasive surgery J Telemed Telecare 2000 6(Suppl 2):S88 9 10975118
Masero V, Sanchez FM, Uson J A telemedicine system for enabling teaching activities J Telemed Telecare 2000 6(Suppl 2):S86 8 10975117
Massman NJ, Dodge JD, Fortman KK, et al Burns follow-up: an innovative application of telemedicine J Telemed Telecare 1999 5(Suppl 1):S52 4 10534841
Masys DR Advances in information technology. Implications for Med Educ West J Med 1998 168(5):341 7 9614791 1304977
Mavrogeni SI, Tsirintani M, Kleanthous C, et al Supervision of thrombolysis of acute myocardial infarction using telemedicine J Telemed Telecare 2000 6(1):54 8 10824393
May C, Gask L, Ellis N, et al Telepsychiatry evaluation in the north-west of England: preliminary results of a qualitative study J Telemed Telecare 2000 6(Suppl 1):S20 2
Mayer M, Till JE The Internet: a modern Pandora's box? Qual Life Res 1996 5(6):568 71 8993102
Mazur DJ Judgmental psychology, law, and ethics Med Decis Making 1998 18(3):354 5 9680002
McCormack J Moving beyond billboards Health Data Manag 1997 5(10):132 4 10175740
McCormack J Why build an interactive site? Health Data Manag 1999 7(3):82 3 10539182
McCray AT Improving access to healthcare information: the Lister Hill National Center for Biomedical Communications MD Comput 2000 17(2):29 34 10778296
McCutcheon JC, Schumacher DN Health care transformation and the case for a community-wide health information management environment Qual Manage Health Care 1994 2(4):1 17
McDaniel JG, Moehr JR, Muller HA Impediments to developing wide area networks in health care MEDINFO 1995 8(Pt 2):1491 5 8591481
McGowan J, Evans J, Michl K. Networking a need: a cost-effective approach to statewide health information delivery. Proc Ann Symposium Comput App Med Care. 1995:571-5.
McKay HG, Feil EG, Glasgow RE, et al Feasibility and use of an Internet support service for diabetes self-management Diabetes Educator 1998 24(2):174 9 9555356
McKenas DK The future of commercial aviation medicine Aviat Space Environ Med 2000 71(4):441 2 10766472
McLaren P, Ball CJ, Summerfield AB, et al An evaluation of the use of interactive television in an acute psychiatric service J Telemed Telecare 1995 1(2):79 85 9375124
McLaren P, Mohammedali A, Riley A, et al Integrating interactive television-based psychiatric consultation into an urban community mental health service J Telemed Telecare 1999 5(Suppl 1):S100 2 10534861
McLaren P, Wootton R Interactive television and the NHS: too much television could be bad for your health [editorial] J Roy Soc Med 1998 91(10):510 2 10070368 1296906
McLaren PM, Blunden J, Lipsedge ML, et al Telepsychiatry in an inner-city community psychiatric service J Telemed Telecare 1996 2(1):57 9 9375043
McLaren PM, Laws VJ, Ferreira AC, et al Telepsychiatry: outpatient psychiatry by videolink J Telemed Telecare 1996 2(Suppl 1):59 62 9375094
McLellan F. "Like hunger, like thirst": patients, journals, and the internet. Lancet. 1998:SII39-43.
McLeod SD The quality of medical information on the Internet. A new public health concern [editorial] Arch Ophthalmol 1998 116(12):1663 5 9869800
McMinn B How do you eat an elephant? Caring 1997 16(4):12 4 10167037
McNamara DM Health-oriented telecommunication: a community resource Nurs Manage 1994 25(12):40 1 7800296
McRoy SW, Liu-Perez A, Ali SS Interactive computerized health care education J Am Med Inform Assoc 1998 5(4):347 56 61312 9670132
McTighe K Internet-healthcare: ultimate savior of the system? Health Manage Technol 1999 20(11):24 7
Mechanic D Public trust and initiatives for new health care partnerships Milbank Q 1998 76(2):281 302 9614423
Mehta MP, Sinha P, Kanwar K, et al Evaluation of Internet-based oncologic teaching for medical students J Cancer Educ 1998 13(4):197 202 9883777
Mekhjian H, Turner JW, Gailiun M, et al Patient satisfaction with telemedicine in a prison environment J Telemed Telecare 1999 5(1):55 61 10505370
Meltzer B Telemedicine in emergency psychiatry Pyschiatr Ser 1997 48(9):1141 1142
Mena A, Diez Ballesteros JL METROPOLIS: telecommunications services for health care added value (strategies for telematics systems in metropolitan areas to improve health care delivery Comput Methods Programs Biomed 1994 45(1-2):121 2 7889742
Menduno M Empowering patients Hosp Health Netw 2000 74(3):18 20 10776373
Merritt R. Managed care organizations and the electronic highway: a study on the requirements for a value added network. In: Navigating reform: HMOs and managed care in a time of transition: proceedings of the 44th Annual Group Health Institute, June. 1994;1994:299-321.
Messick P Innovative ways of responding to change Hosp Food Nutr Focus 1996 12(10):1 2 10157813
Meyer C Sixteen ways to blur your organization: a conversation with Chris Meyer [interview by Joe Flower] Healthc Forum J 1999 42(1):12 6
Meyer CR Medical consumers browse a chaotic cyberspace Minnesota Med 2000 83(4):12 6, 18 10783599
Michelson G, Striebel W, Prihoda W, et al Telemedicine in the control of intra-ocular pressure J Telemed Telecare 2000 6(Suppl 1):S126 8 10793996
Mielonen ML, Ohinmaa A, Moring J, et al Psychiatric inpatient care planning via telemedicine J Telemed Telecare 2000 6(3):152 7 10912333
Miglak G Take a holistic view when planning your network Health Manage Technol 1996 17(11):40 1
Miles DA, Razzano MR The future of digital imaging in dentistry Dent Clin North Am 2000 44(2):427 38, viii 10740777
Miles SM. A case study: telemedicine equipment trial and applications development. In: Proceedings of the. 1995;1995:181-90.
Miller G Supplying provider data via the Internet Health Manage Technol 1998 19(9).
Millman M, editor. Access to Health Care in America. Washington, DC: National Academy Press; 1993.
Mitchell J Increasing the cost-effectiveness of telemedicine by embracing e-health J Telemed Telecare 2000 6(Suppl 1):S16 9 10793960
Mitchell J, Robinson P, Seiboth C, et al An evaluation of a network for professional development in child and adolescent mental health in rural and remote communities J Telemed Telecare 2000 6(3):158 62 10912334
Mitchell JG, Disney AP, Roberts M Renal telemedicine to the home J Telemed Telecare 2000 6(1):59 62 10824394
Mitka M Weaving webs for physicians [news] JAMA 1999 281(12):1070 1 10188644
Miyasaka K, Suzuki Y, Sakai H, et al Interactive communication in high-technology home care: videophones for pediatric ventilatory care Pediatrics 1997 99(1):
Mizuno-Matsumoto Y, Date S, Tabuchi Y, et al Telemedicine for evaluation of brain function by a metacomputer IEEE Trans Inf Technol Biomed 2000 4(2):165 72 10866416
Mizushima H, Uchiyama E, Nagata H, et al Telemedicine comes of age [editorial] Jpn J Clin Oncol 2000 30(1):3 6 10770560
Mogli GD Challenges of health care delivery system beyond 2000 AD Ihrim 1998 39(4):14 7 10344799
Monsen RB Genetics and health care [editorial] Journal of Pediatric Nursing 1999 14(2):71 2 10337116
Montani C, Billaud N, Tyrrell J, et al Psychological impact of a remote psychometric consultation with hospitalized elderly people J Telemed Telecare 1997 3(3):140 5 9489108
Moore P Third generation Web marketing. Siskin Hospital for Physical Rehabilitation, Chattanooga, TN Profiles Healthc Mark 1997 13(3):29 34 10167486
Moralis M Benchmarking Web sites Hosp Q 1998 1(3):80 2 10345589
Moralis M Healthcare economics vs. economics of healthcare Hosp Q 1998 1(4):68 70 10345313
Moralis M Top 10 web sites for hospital managers Hosp Q 1997 1(1):46 9 10345280
Morlion B, Verbandt Y, Paiva M, et al A telemanagement system for home follow-up of respiratory patients IEEE Eng Med Biol Mag 1999 18(4):71 9 10429904
Morris DG Using telemedicine to facilitate training in cardiotocography (CTG) interpretation J Telemed Telecare 2000 6(Suppl 1):S53 5 10793972
Morris DG, Hayward T Enhancement of an antenatal diagnosis and counselling service (ADACS) through the ready availability of telemedicine services J Telemed Telecare 2000 6(Suppl 1):S56 8
Morrison I The 1 percent problem. The organization of medicine has changed little in a century Healthc Forum J 1999 42(4):42 6
Morrissey J 2020 visions. Just a click away Mod Healthc 1999 29(39):5 7 10621428
Morrissey J Securing the Internet frontier Mod Healthc 1996 26(43):56 8
Morrissey J Stalled on the on-ramp. Many in healthcare aren't on the data superhighway [news] Mod Healthc 1997 27(10):
Moyer CA, Katz SJ, Williams B, et al. The effect of facilitated E-mail access on patient and resident physician communication and satisfaction [abstract]. Ann Meeting Int Soc Technol Assess Health Care. 15.
Moynihan JJ, Norman K Healthcare EDI (electronic data interchange)-the transatlantic experience Healthc Financ Manage 1993 47(6):139 40 10145820
Muir Gray JA, de Lusignan S National electronic Library for Health (NeLH) [published erratum appears in BMJ 2000 Jan 29;320(7230):296] BMJ 1999 319(7223):1476 9 10582933 1117204
Mullen P Web site helps Californians become informed purchasers of health care Managed Care 1997 6(4).
Mullich J Patient heal thyself Healthcare Inform 1997 14(7):27 8
Murdoch I, Bainbridge J, Taylor P, et al Postoperative evaluation of patients following ophthalmic surgery J Telemed Telecare 2000 6(Suppl 1):S84 6 10793982
Murphy JM, O'Hare NJ, Wheat D, et al Digitized mammograms: a preliminary clinical evaluation and the potential for telemammography J Telemed Telecare 1999 5(3):193 7 10628036
Nagata H, Mizushima H A remote collaboration system for telemedicine using the Internet J Telemed Telecare 1998 4(2):89 94 9744164
Nagata H, Mizushima H World wide microscope: new concept of internet telepathology microscope and implementation of the prototype MEDINFO 1998 9(Pt 1):286 9 10384463
Nagendran S, Moores D, Spooner R, et al Is telemedicine a subset of medical informatics? J Telemed Telecare 2000 6(Suppl 2):S50 1
Nakagawa A, Marks IM, Park JM, et al Self-treatment of obsessive-compulsive disorder guided by manual and computer-conducted telephone interview J Telemed Telecare 2000 6(1):22 6 10824386
Nakajima I, Yamamoto I, Kato H, et al Study for verification testing of the helmet-mounted display in the Japanese Experimental Module J Med Syst 2000 24(1):1 9 10782438
Nakamura K, Takano T, Akao C The effectiveness of videophones in home healthcare for the elderly Med Care 1999 37(2):117 25 10024116
Nater T Where is physician leadership in the e-health community? Hosp Pract 2000 35(5):
Nesbitt TS, Hilty DM, Kuenneth C, et al. Development of a telemedicine program. West J Med. 2000;173:169-174. [pmid: 10986176].
Niles S, Alemagno S, Stricklin ML Healthy talk: a telecommunication model for health promotion Caring 1997 16(7):46 50
Nobel JJ The health care professional's workstation: a call to action Int J Biomed Comput 1994 34(1-4):21 8 8125634
Nobel JJ, Cherry JC IT helps manage patients with chronic illness Health ManageTechnol 1999 20(11):38 40
Nohr LE Global medicine and licensing J Telemed Telecare 2000 6(Suppl 1):S170 2 10794010
Nohr LE Telemedicine and patients' rights J Telemed Telecare 2000 6(Suppl 1):S173 4 10794011
Nordhaus-Bike AM On the Internet. It takes a 'virtual village' Hosp Health Netw 1996 70(7):
Nugent D Providing solutions for the growing trend toward home healthcare Health Manage Technol 1999 20(8).
O'Connor D, Peterson C, Whitfield J Telehealth. What does it offer for public health care? Aust Fam Physician 2000 29(5):403 4 10835774
O'Mahony B User centred health care [editorial] Irish Med J 2000 93(1):
O'Neill SK, Allen D, Brockway PD The design and implementation of an off-the-shelf, standards-based tele-ultrasound system J Telemed Telecare 2000 6(Suppl 2):S52 3 10975102
O'Shannessy L Using the law to enhance provision of telemedicine J Telemed Telecare 2000 6(Suppl 1):S59 62 10793974
Oakley AM, Kerr P, Duffill M, et al Patient cost-benefits of realtime teledermatology-a comparison of data from Northern Ireland and New Zealand J Telemed Telecare 2000 6(2):97 101 10824377
Ogushi Y, Misawa T, Hayashi Y, et al Regional medical information network using optical memory cards and integrated services for digital network MEDINFO 1995 8(Pt 2):1535 7 8591493
Oki Y, Shiomi T, Sasanabe R, et al Multiple cardiovascular risk factors in obstructive sleep apnea syndrome patients and an attempt at lifestyle modification using telemedicine-based education Psychiatry Clin Neurosci 1999 53(2):311 3 10459721
Oliver C Automatic replies can be sent to unsolicited email from general public [letter] BMJ 1999 319(7222):28276
Olsen DR, Bruland S, Davis BJ Telemedicine in radiotherapy treatment planning: requirements and applications Radiother Oncol 2000 54(3):255 9 10738084
Olver IN, Selva-Nayagam S Evaluation of a telemedicine link between Darwin and Adelaide to facilitate cancer management Telemed J 2000 6(2):213 8 10957733
Orthner HF, Scherrer JR, Dahlen R Sharing and communicating health care information: summary and recommendations Int J Biomed Comput 1994 34(1-4):303 18 8125644
Orvell B The next transformation in the delivery of health care [letter; comment] New Eng J Med 1995 332(16):
Ostojic V, Stipic-Markovic A, Tudman Z, et al A feasibility study of realtime telemedicine in Croatia using Internet videoconferencing J Telemed Telecare 2000 6(3):172 6 10912337
Ozok AA, Salvendy G Measuring consistency of web page design and its effects on performance and satisfaction Ergonomics 2000 43(4):443 60 10801079
Pace K, Dittbrenner H Electronic data interchange-a vision for health care Caring 1993 12(7):14 6
Pak HS, Welch M, Poropatich R. Web-based teledermatology consult system: preliminary results from the first 100 cases. Stud Health Technol Inform. 1999;64:179-84. [pmid: 10747537].
Pandolfini C, Impicciatore P, Bonati M Parents on the web: risks for quality management of cough in children Pediatrics 2000 105(1):
Papakostopoulos D, Hart JC, Papakostopoulos S, et al Standardized visual evoked potentials for telematic electrodiagnosis from five laboratories in three European countries J Telemed Telecare 1999 5(1):23 31 10505366
Papakostopoulos D, Ramani V, Papakostopoulos S, et al Telematic electrodiagnosis from six laboratories in three European countries and one Asian country J Telemed Telecare 1998 4(Suppl 1):23 4 9640723
Paperny DM Computers and information technology: implications for the 21st century Adolesc Med 2000 11(1):183 202 10640346
Park IB Innovation can be either low-tech or high-tech Tenn Med 1998 91(2):52 3 9478121
Pasternack A Software support. Hung up on response time Hosp Health Netw 1998 72(9):
Patel T A cost-benefit analysis of the effect of shipboard telemedicine in a selected oceanic region J Telemed Telecare 2000 6(Suppl 1):S165 7 10794008
Patil RS, Silva JS, Swartout WR An architecture for a health care provider's workstation Int J Biomed Comput 1994 34(1-4):285 99 8125640
Patrick K Information technology and the future of preventive medicine: potential, pitfalls, and policy Am J Prev Med 2000 19(2):132 5 10913905
Patterson S, Botchway C Dental screenings using telehealth technology: a pilot study J Can Dent Assoc 1998 64(11):806 10 9879146
Pavia L Health care's top 10 trends that should ride into next decade Health Care Strateg Manage 1999 17(4):12 3 10538112
Pazzi S, Cristiani P, Cavallini A A national neurological excellence centers network Cephalalgia 1998 18(Suppl 21):70 2 9533676
Pedersen S, Hartviksen G, Haga D Teleconsultation of patients with otorhinolaryngologic conditions. A telendoscopic pilot study Arch Otolaryngol Head Neck Surg 1994 120(2):133 6 8297568
Peifer J, Hopper A, Sudduth B. A patient-centric approach to telemedicine database development. Stud Health Technol Inform. 1998;50:67-73. [pmid: 10180588].
Pennbridge J, Moya R, Rodrigues L Questionnaire survey of California consumers' use and rating of sources of health care information including the Internet West J Med 1999 171(5-6):302 5 10639865 1308740
Peppers D, Rogers M, Adamson G One-to-one: knocking on healthcare's door Healthc Forum J 1998 41(1):31 3 10185482
Peschel KM, Reed WC, Salter K Integrating heterogeneous healthcare call centers Healthc Inf Manage 1998 12(2):29 40 10182516
Petersen I, Wolf G, Roth K, et al Telepathology by the Internet J Pathol 2000 191(1):8 14 10767712
Peterson C Laptops and health care: going mobile HMO 1995 36(2):11 3
Pham B, Yearwood J Delivery and interactive processing of visual data for a cooperative telemedicine environment Telemed J 2000 6(2):261 8 10957739
Phillips VL, Temkin AJ, Vesmarovich SH, et al A feasibility study of video-based home telecare for clients with spinal cord injuries J Telemed Telecare 1998 4(4):219 23 10505358
Piccolo D, Smolle J, Argenziano G, et al Teledermoscopy-results of a multicentre study on 43 pigmented skin lesions J Telemed Telecare 2000 6(3):132 7 10912329
Pickering TG, Gerin W, Holland JK Home blood pressure teletransmission for better diagnosis and treatment Current Hypertension Reports 1999 1(6):489 94 10981111
Picot J Meeting the need for educational standards in the practice of telemedicine and telehealth J Telemed Telecare 2000 6(Suppl 2):S59 62 10975105
Piette JD Moving diabetes management from clinic to community: development of a prototype based on automated voice messaging Diabetes Educator 1997 23(6):672 80 9416031
Piette JD, Weinberger M, McPhee SJ The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: a randomized, controlled trial Med Care 2000 38(2):218 30 10659695
Pisano ED, Yaffe MJ, Hemminger BM, et al Current status of full-field digital mammography Acad Radiol 2000 7(4):266 80 10766101
Popescu VG, Burdea GC, Bouzit M, et al A virtual-reality-based telerehabilitation system with force feedback IEEE Trans Inf Technol Biomed 2000 4(1):45 51 10761773
Porcelli PJ, Lobach DF. Integration of clinical decision support with on-line encounter documentation for well child care at the point of care. Proc AMIA Ann Symposium. 1999:599-603.
Poste G Molecular medicine and information-based targeted healthcare Nature Biotechnol 1998 16(Suppl):19 21 9591257
Prochaska JJ, Zabinski MF, Calfas KJ, et al PACE+: interactive communication technology for behavior change in clinical settings Am J Prev Med 2000 19(2):127 31 10913904
Pryor D 21st century information systems for integrated delivery systems Behav Healthc Tomorrow 1996 5(6):78 9
Quaglini S, Dazzi L, Gatti L, et al Supporting tools for guideline development and dissemination Artif Intell Med 1998 14(1-2):119 37 9779886
Quaglini S, Dazzi L, Stefanelli M, et al Decision support systems in Health Econ Top Health Inf Manage 1999 20(1):16 30 10539420
Quast A Telehealth and state licensure [letter; comment] Nurse Pract 1999 24(8):12 3 10479107
Rainey M, Bailey M, Hartley S Enabling information technologies for home care Healthc Inf Manage 1996 10(2):43 8
Rashbass J The impact of information technology on histopathology Histopathology 2000 36(1):1 7 10632745
Reddy ER, Bartlett PJ, Harnett JD, et al Telemedicine and fetal ultrasonography in a remote Newfoundland community [letter] Can Med Assoc J 2000 162(2):206 7 10674053 1232270
Reddy R, Jagannathan V, Srinivas K, et al. ARTEMIS: a collaborative framework for health care. Proc Ann Symposium Comput Appl Med Care. 1993:559-63.
Reina-Tosina J, Roa L, Rovayo M NEWBET: telemedicine platform for burn patients IEEE Trans Inf Technol Biomed 2000 4(2):173 7 10866417
Rendina MC. The effect of telemedicine on neonatal intensive care unit length of stay in very low birthweight infants. ProcAMIA Ann Symposium. 1998:111-5.
Rendina MC, Long WA, deBliek R Effect size and experimental power analysis in a paediatric cardiology telemedicine system J Telemed Telecare 1997 3(Suppl 1):56 7 9218385
Reponen J, Ilkko E, Jyrkinen L, et al Digital wireless radiology consultations with a portable computer J Telemed Telecare 1998 4(4):201 5 10505355
Reponen J, Ilkko E, Jyrkinen L, et al Initial experience with a wireless personal digital assistant as a teleradiology terminal for reporting emergency computerized tomography scans J Telemed Telecare 2000 6(1):45 9 10824391
Reynolds JT The next transformation in the delivery of health care [letter; comment] New Eng J Med 1995 332(16):
Ricke J, Bartelink H Telemedicine and its impact on cancer management Eur J Cancer 2000 36(7):826 33 10785586
Rigby M The management and policy challenges of the globalisation effect of informatics and telemedicine Health Policy 1999 46(2):97 103 10346288
Rigby M, Birch K, Roberts R The need to ensure that the globalization of information and telematics does not destabilize health-care worldwide J Telemed Telecare 2000 6(Suppl 1):S116 8 10793993
Rissam HS, Kishore S, Bhatia ML, et al Trans-telephonic electrocardiographic monitoring-experience in India J Telemed Telecare 1998 4(Suppl 1):8 11 9640718
Rissam HS, Kishore S, Srivastava S, et al Evaluation of cardiac symptoms by trans-telephonic electro-cardiographic monitoring (TTEM): preliminary experience Indian Heart J 1998 50(1):55 8 9583288
Robert G, Stevens A, Gabbay J 'Early warning systems' for identifying new healthcare technologies Health Technol Assess 1999 3(13):1 108
Roberts J. Are healthcare professionals really prepared to deal with information-empowered citizens?. Stud Health Technol Inform. 1999;68:523-7. [pmid: 10724943].
Rockefeller RG The next transformation in the delivery of health care [letter; comment] New Eng J Med 1995 332(16):1099 100 7898534
Rohland BM, Saleh SS, Rohrer JE, et al Acceptability of telepsychiatry to a rural population Pyschiatr Ser 2000 51(5):672 4
Rollins S Technology on the move: eliminating paper at the point of care Healthcare Inform 1994 11(5).
Ronco C, Brendolan A, Bellomo R Online monitoring in continuous renal replacement therapies Kidney Int 1999 56(Suppl 72):S8 14
Rosen E 1999: the year of ADSL? Telemed Today 1998 6(2):22 5
Rosen PN Workstations as enabling technologies for computer-based patient records Int J Biomed Comput 1994 34(1-4):335 7 8125647
Rosoff AJ Informed consent in the electronic age Am J Law Med 1999 25(2-3):367 86 10476334
Rosser JC, Jr., Bell RL, Harnett B, et al Use of mobile low-bandwith telemedical techniques for extreme telemedicine applications J Am Coll Surg 1999 189(4):397 404 10509466
Rosser JC, Jr., Prosst RL, Rodas EB, et al Evaluation of the effectiveness of portable low-bandwidth telemedical applications for postoperative followup: initial results J Am Coll Surg 2000 191(2):196 203 10945365
Roth A, Malov N, Carthy Z, et al Potential reduction of costs and hospital emergency department visits resulting from prehospital transtelephonic triage-the Shahal experience in Israel Clin Cardiol 2000 23(4):271 6 10763075
Rubin RD A customer view of CHINs [comment] Front Health Serv Manage 1995 12(1):44 9 10144790
Ruffin M Intranets advance Med Care Phys Exec 1996 22(6):32 7
Ruffin M, Jr Preparing for managed competition Phys Exec 1994 20(1):29 35
Ruggiero C, Sacile R, Giacomini M Home telecare J Telemed Telecare 1999 5(1):11 7 10505364
Russo H Leveraging health care processes using technology applications Caring 2000 19(1):26 9 10787816
Russon N Linking the healthcare continuum with technology International J Health Care Qual Assur 1997 10(1).
Sable C, Roca T, Gold J, et al Live transmission of neonatal echocardiograms from underserved areas: accuracy, patient care, and cost Telemed J 1999 5(4):339 47 10908449
Saeki K, Izumi H, Ohyanagi T, et al Distance education for health centre staff in rural Japan J Telemed Telecare 2000 6(Suppl 2):S67 9 10975108
Safran C Defining clinical 'workstation' Int J Biomed Comput 1994 34(1-4):261 5 8125637
Sakashita Y, Ogushi Y, Okada Y, et al Health and welfare data on optical memory cards in Isehara city Med Inform 1996 21(1):69 79
Salmon S, Brint G, Marshall D, et al Telemedicine use in two nurse-led minor injuries units J Telemed Telecare 2000 6(Suppl 1):S43 5
Saltz JH Digital pathology-the big picture [editorial] Hum Pathol 2000 31(7):779 80 10923911
Sandberg L Managing congestive heart failure with telemedicine Health Manage Technol 2000(July):
Sandgren AK, McCaul KD, King B, et al Telephone therapy for patients with breast cancer Oncol Nurs Forum 2000 27(4):683 8 10833696
Sandrick K Dreaming up new home care solutions Health Manage Technol 1998 19(10):20 3
Sandrick K Internet marketing: software for the hard sell Health Manage Technol 1998 19(11):16 8
Santarelli MF, Positano V, Landini L Combining high-performance computing and networking for advanced 3-D cardiac imaging IEEE Trans Inf Technol Biomed 2000 4(1):58 67 10761775
Sawada I, Sugiyama A, Ishikawa A, et al Upgrading rural Japanese nurses' respiratory rehabilitation skills through videoconferencing J Telemed Telecare 2000 6(Suppl 2):S69 71
Scalera N Telecommunications needs in the home care environment Healthcare Inform 1993 10(8):42 4
Schachinger U, Kretschmer R, Rockelein W, et al NOAH-A mobile emergency care system Eur J Med Res 2000 5(1):13 8 10657283
Schantz M An alternate road home to electronic media claims Caring 1993 12(7):38 40 10127005
Scherrer JR, Spahni S New opportunities for processing the OSI-7 layer protocols using parallel processing (transputers) Int J Biomed Comput 1994 34(1-4):387 98 8125653
Scherrer-Bannerman A, Fofonoff D, Minshall D, et al Web-based education and support for patients on the cardiac surgery waiting list J Telemed Telecare 2000 6(Suppl 2):S72 4 10975110
Schiff L What's up on the Web Bus Health 1997 15(12):33 4 10175497
Schiller A, Jr., Andrew W The CPR: a patient perspective Healthcare Inform 1996 13(3).
Schmid-Grendelmeier P, Masenga EJ, Haeffner A, et al Teledermatology as a new tool in sub-saharan Africa: an experience from Tanzania J Am Acad Dermatol 2000 42(5 Pt 1):833 5 10775865
Schneider P Cyberhealth or cyberhysteria? Healthcare Inform 1996 13(6):58 60
Schneider P Patient informatics in growing Healthcare Inform 1997 14(8).
Schneider P Web tools target patients Healthcare Inform 1998 15(7):23 4
Schoech D, Cavalier A, Hoover B A model for integrating technology into a multi-agency community service delivery system Assistive Technol 1993 5(1):11 23
Schoenfelt SJ. That was then, this is now: new ways to collect the data. Infocare. 1997:Sep-Oct.
Scholz T, Kienzle M Optimizing utilization of pediatric echocardiography and implications for telemedicine Am J Cardiol 1999 83(12):1645 8 10392869
Schopp LH, Johnstone BR, Merveille OC Multidimensional telecare strategies for rural residents with brain injury J Telemed Telecare 2000 6(Suppl 1):S146 9 10794002
Schubert A Teleconferencing, distance learning, and telementoring: new technology harnessed for perioperative education [editorial] J Clin Anesth 2000 12(3):250 1 10869929
Schwartz F, Genovese L, Devitt K, et al Multisite regional telephone care Nurs Clin North Am 2000 35(2):527 39 10873265
Schwartz SD, Harrison SA, Ferrone PJ, et al Telemedical evaluation and management of retinopathy of prematurity using a fiberoptic digital fundus camera Ophthalmology 2000 107(1):25 8 10647714
Sconyers JM Developing a healthcare law library J Health Law 1998 31(3):315 32 10620833
Sengupta S, Clayton PD, Molholt P, et al IAIMS and sharing Int J Biomed Comput 1994 34(1-4):339 48 8125648
Sennett C Ambulatory care in the new millennium: the role of consumer information Qual Manage Health Care 2000 8(2):82 7
Shani M [The changing world (editorial)] Harefuah 1997 133(7-8):
Sharma DC Remote Indian villages to benefit from telemedicine project [news] Lancet 2000 355(9214):
Shimizu K Telemedicine by mobile communication IEEE Eng Med Biol Mag 1999 18(4):32 44 10429900
Shortliffe EH Health care and the next generation Internet [editorial; comment] Ann Intern Med 1998 129(2):138 40 9669975
Shortliffe EH Health care professional workstations: where are we now? ... where should we be tomorrow? Int J Biomed Comput 1994 34(1-4):45 55 8125654
Shropshire S Not so lovely spam CIN Plus 1999 2(1):
Sikdar S Psychiatry, the Internet and the public [letter] Hosp Med (Lond) 1998 59(6):
Silva JS, Ball MJ The professional workstation as enabler: conference recommendations. International Medical Informatics Association Int J Biomed Comput 1994 34(1-4):3 10
Silverman BG, Andonyadis C, Morales A Web-based health care agents; the case of reminders and todos, too (R2Do2) Artif Intell Med 1998 14(3):295 316 9821519
Simon P [Smart card systems in health care (protection, key-functions, divided data bases, applications)] Orvosi Hetilap 1999 140(17):947 52 10344142
Simpson RL Technology: nursing the system. Case-managed care in tomorrow's information network Nurs Manage 1993 24(7):14 6
Singh T, Natu MV Distance education for better health care [editorial] Indian Pediatr 1997 34(9):773 7 9492414
Siwicki B A different kind of house call Health Data Manag 1999 7(1):28 9
Siwicki B With worries galore, should health care rely on the Internet? Health Data Manag 1998 6(12):26 8 10187486
Sixsmith A, Sixsmith J Smart care technologies: meeting whose needs? J Telemed Telecare 2000 6(Suppl 1):S190 2 10794016
Sixsmith AJ An evaluation of an intelligent home monitoring system J Telemed Telecare 2000 6(2):63 72 10824373
Slack WV The patient online [comment] Am J Prev Med 1999 16(1):43 5 9894554
Slomka PJ, Elliott E, Driedger AA Java-based remote viewing and processing of nuclear medicine images: toward "the imaging department without walls" J Nucl Med 2000 41(1):111 8 10647613
Smith J "Internet patients" turn to support groups to guide medical decisions [news] J Natl Cancer Inst 1998 90(22):1695 7 9827520
Smith J, Velez M, Landsitte M Software for the competitive edge Caring 1997 16(12):42 4
Smith JL The DoD arrives just-in-time Health Syst Rev 1994 27(1):38 9 10131570
Smith R Health care in the next millennium Eur J Nucl Med 2000 27(1 Suppl):S17 20 10744466
Snook A Promises, promises Nurs Times 1999 95(45):44 5 11000801
Soetikno RM, Provenzale D, Lenert LA Studying ulcerative colitis over the World Wide Web Am J Gastroenterol 1997 92(3):457 60 9068469
Sogner P, Goidinger K, Reiter D, et al Security aspects of teleradiology between the university centre and outlying hospitals in Tyrol J Telemed Telecare 2000 6(Suppl 1):S160 1 10794006
Solomon DK, Gourley DR, Brown JR, et al Technology assessment and the drug use process Am J Manag Care 1999 5(2):220 9 10346517
Solovy A Bandwidth & bandwagon Hosp Health Netw 2000 74(3):34 6
Sommer TJ Telemedicine: a useful and necessary tool to improving quality of healthcare in the European Union Comput Methods Programs Biomed 1995 48(1-2):73 7 8846716
Souhrada L Closing the loop. Hospitals prepare for EHCR (efficient healthcare consumer response) Mat Manage Health Care 1997 6(7).
Souhrada L Computer survey: gains made, but work remains Mat Manage Health Care 1993 2(1):20 4
Souhrada L Easy touch. Computer survey update Mat Manage Health Care 1996 5(10):16 9
Spielberg AR Online without a net: physician-patient communication by electronic mail Am J Law Med 1999 25(2-3):267 95 10476331
Squibb NJ Video transmission for telemedicine J Telemed Telecare 1999 5(1):1 10 10505363
Stahl JN, Zhang J, Zellner C, et al Teleconferencing with dynamic medical images IEEE Trans Inf Technol Biomed 2000 4(2):88 96 10866407
Stamford P, Bickford T, Hsiao H, et al The significance of telemedicine in a rural emergency department IEEE Eng Med Biol Mag 1999 18(4):45 52 10429901
Stammer L Healthcare from a distance Hospital Practice (Office Edition) 2000 35(5):25 6
Stanberry B Telemedicine: barriers and opportunities in the 21st century Journal of Internal Medicine 2000 247(6):615 28 10886483
Stanberry B, Rossignol G, Menke P Contracting with health-care customers and specialists for the provision of telemedicine services across European borders: the TEN-Telemed Legal Project J Telemed Telecare 2000 6(Suppl 1):S104 6 10793989
Stead WW The networked health enterprise: a vision for 2008 J Am Med Inform Assoc 1998 5(5):412 5 61321 9760388
Steenhuysen J Provider automation. The secret to better cash flow Health Data Manag 1995 3(2):28 9
Stensgaard T Telemedicine in Greenland-from the early beginnings to the making of a business plan J Telemed Telecare 2000 6(Suppl 1):S158 9 10794005
Stevens A, Milne R, Lilford RJ, et al. Keeping pace with new technologies: systems needed to identify and evaluate them. BMJ. 1999;319:1291-5. [pmid: 10559044]. [pmcid: 1129069].
Stevens L A primer on Internet-based patient education Medical Management Network 1998 6(7):6 9 10182262
Strauchen JA Further "teleconsultation" called for [letter; comment] Am J Clin Pathol 2000 113(4):
Strode SW, Gustke S, Allen A Technical and clinical progress in telemedicine JAMA 1999 281(12):1066 8 10188642
Stroetmann KA, Gruetzmacher P, Stroetmann VN Improving quality of life for dialysis patients through telecare J Telemed Telecare 2000 6(Suppl 1):S80 3
Strum S Consultation and patient information on the Internet: the patients' forum Br J Urol 1997 80(Suppl 3):22 6 9415081
Studies of patient satisfaction with telemedicine are inconclusive BMJ 2000 320(June 3):27404
Suarez-Almazor ME, Kendall CJ, Dorgan M. Surfing the Net: information on the World Wide Web for patients with arthritis [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 15.
Suleiman AB Missions of a medical school: an Asian perspective Acad Med 1999 74(8 Suppl):S45 52 10495743
Sutherland L, Igras E, Ulmer R, et al A laboratory for testing the interoperability of telehealth systems J Telemed Telecare 2000 6(Suppl 2):S74 5
Suttenfield K Extreme telemedicine, Everest style MD Comput 1999 16(4):35 7 10507235
Tachakra S, Dawood M Telemedicine-the technology and its applications Emergency Nurse 2000 7(10):6 8 10847015
Tachakra S, Dutton D, Newson R, et al How do teleconsultations for remote trauma management change over a period of time? J Telemed Telecare 2000 6(Suppl 1):S12 5 10793959
Tachakra S, Jaye P, Bak J, et al Supervising trauma life support by telemedicine J Telemed Telecare 2000 6(Suppl 1):S7 11 10793958
Tachakra S, Lynch M, Newson R, et al A comparison of telemedicine with face-to-face consultations for trauma management J Telemed Telecare 2000 6(Suppl 1):S178 81 10794013
Tachakra S, Wiley C, Dawood M, et al Evaluation of telemedical support to a free-standing minor accident and treatment service J Telemed Telecare 1998 4(3):140 5 10321041
Tachinardi U Internet and healthcare in Brazil: the role of the Working Group for Healthcare (GT Saude) Comput Biol Med 1998 28(5):519 29 9861509
Tamai U, Nakagawa K, Yokomori M, et al A conference support system for telehealth J Telemed Telecare 2000 6(Suppl 2):S76 8 10975112
Tang P, Venables T 'Smart' homes and telecare for independent living J Telemed Telecare 2000 6(1):8 14 10824384
Taylor P An assessment of the potential effect of a teledermatology system J Telemed Telecare 2000 6(Suppl 1):S74 6 10793979
Terry JB Evolution of neuronetworks Neuroepidemiology 2000 19(1):20 9 10654285
Terry K Now patients will rate you online Med Econ 2000 77(8):45 6
Terry NP Cyber-malpractice: legal exposure for cybermedicine Am J Law Med 1999 25(2-3):327 66 10476333
Thobaben M Common phobias Home Care Provid 1997 2(5):215 7 9362674
Thomas C, Prasanna M The role of a 'satellite-service' in the national organisation of burn care in the Sultanate of Oman Burns 2000 26(2):181 5 10716362
Thomas R, Thornton H, Mackay J Patient information materials in oncology: are they needed and do they work? Clin Oncol 1999 11(4):225 31
Thurlow KL Caring for patients with latex allergies Home Healthc Nurse 1999 17(10):625 9 10818836
Tickle M, Jenner T, Rolfe P, et al Toward a standardised information system for dentistry Br Dent J 1998 184(10):472 3 9642861
Timpka T, Sjoberg C Development of systems for support of collaboration in health care: the design arenas Artif Intell Med 1998 12(2):125 36 9520220
Tomlin AC Cheaper by the dozen: low cost consumer health resources Natl Netw 1998 23(2):9 10 10185880
Torok M, Kovacs F, Doszpod J Cost-effectiveness of home telemedical cardiotocography compared with traditional outpatient monitoring J Telemed Telecare 2000 6(Suppl 1):S69 70
Torok M, Turi Z, Kovacs F Ten years' clinical experience with telemedicine in prenatal care in Hungary J Telemed Telecare 1999 5(Suppl 1):S14 7
Toubiana L, Vibert JF, Garnerin P, et al SITIE: a health care workstation integration architecture for epidemiologists Comput Biomed Res 1995 28(2):100 15 7656548
Tsagaris MJ, Papavassiliou MV, Chatzipantazi PD, et al The contribution of telemedicine to cardiology J Telemed Telecare 1997 3(Suppl 1):63 4
Tsuchihashi Y, Okada Y, Ogushi Y, et al The current status of medicolegal issues surrounding telepathology and telecytology in Japan J Telemed Telecare 2000 6(Suppl 1):S143 5 10794001
Tsuchisawa K, Ono K, Kanda T, et al Japanese occupational therapy in community mental health and telehealth J Telemed Telecare 2000 6(Suppl 2):S79 80 10975113
Tucker DA Health care providers riding the information superhighway Home Care Provid 1998 3(5):246 8 10030193
Turchin A, Lehmann CU. Active Learning Centre: utilization patterns of an interactive educational World Wide Web site. Proc AMIA Ann Symposium. 1999:627-31.
Tuttle MS Information technology outside health care: what does it matter to us? J Am Med Inform Assoc 1999 6(5):354 60 61378 10495095
Udvarhelyi IS, Colditz GA, Rai A, et al Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly? Ann Intern Med 1992 116(3):238 44 1530808
Uldal SB A survey of Norwegian telemedicine J Telemed Telecare 1999 5(1):32 7 10505367
Uphoff B, Winn J The health care profit pool: who stands to gain and lose in the digital economy? Healthc Forum J 1999 42(3):46 50
Uto Y, Muranaga F, Kumamoto I, et al. The frontier of nursing in the age of multimedia. Jpn Hosp. 1997;16:69-73. [pmid: 10174053].
Valero MA, Arredondo MT, del Nogal F, et al Patient satisfaction with a home televisiting service based on interactive television over a cable network J Telemed Telecare 2000 6(Suppl 1):S99 101 10793987
van Bemmel JH A model for the assessment of medical workstations for health care support Int J Biomed Comput 1994 34(1-4):365 71 8125651
van der Stelt PF Principles of digital imaging Dent Clin North Am 2000 44(2):237 48, v 10740766
van Heijningen RI, Mannaerts GH, Steffens LF Medicolegal aspects of international teleconsultancy [letter] Lancet 2000 355(9205):757 8
van Leeuwen D, Green P Spotlight on the Internet J Healthc Qual 1998 20(2):Mar Apr
van Mulligen EM, Timmers T, Brand J, et al HERMES: a health care workstation integration architecture Int J Biomed Comput 1994 34(1-4):267 75 8125638
Vandenberg TA, Gustafson DH, Owens B, et al Interaction between the breast cancer patient and the health care system: demands, constraints and options for the future Cancer Prev Control 1997 1(2):152 6 9765739
Vassallo D Use of a digital still camera in surgery [letter] J Telemed Telecare 1999 5(1):
Vercillo DM, Holmes KC, Pingree MJ, et al. Medical student database development: a model for record management in a multi-departmental setting. Proc AMIA Ann Symposium. 1999:979-83.
Vickery K Assisted living goes high tech Provider 1998 24(9):85 7
Vincent JA, Cavitt DL, Karpawich PP Diagnostic and cost effectiveness of telemonitoring the pediatric pacemaker patient Pediatr Cardiol 1997 18(2):86 90 9049117
von Tigerstrom B Current developments in Canadian privacy and information law: implications for telehealth J Telemed Telecare 2000 6(Suppl 2):S83 5 10975115
Wada M, Suzuki R, Murakami T Super-high-definition image systems for telemedicine J Telemed Telecare 2000 6(Suppl 2):
Wade FA, Oliver CW, McBride K Digital imaging in trauma and orthopaedic surgery: is it worth it? J Bone Joint Surg 2000 82(6):791 4
Wadman M Gingrich urges doubling of health funds [news] Nature 1997 390(6658):
Walker GD, Burnham LD Putting the Web to work Caring 1997 16(12):52 4
Wallis JW Java and teleradiology [comment] J Nucl Med 2000 41(1):119 22 10647614
Wan AC, Gul Y, Darzi A Realtime remote consultation in the outpatient clinic-experience at a teaching hospital J Telemed Telecare 1999 5(Suppl 1):S70 1 10534849
Wan AC, Taylor P, Gul Y, et al Sigmoidoscopy in a nurse-practitioner community clinic using telemedicine J Telemed Telecare 1999 5(Suppl 1):S68 9 10534848
Wang J, Naghdy G Three novel lossless image compression schemes for medical image archiving and telemedicine Telemed J 2000 6(2):251 60 10957738
Warren D Online community strengthens the ministry Health Progress 1998 79(6):14 5
Weaver L, Spence D Application of business case analysis in planning a province-wide telehealth network in Alberta J Telemed Telecare 2000 6(Suppl 1):S87 9 10793983
Weber DO The empowered consumer. New demands for access, information and services are changing the face of healthcare delivery Healthc Forum J 1997 40(5):28 33 10170359
Weinel D The Sunshine Network Teleconsultation Initiative for SCI Veterans in Community Settings Sci Nursing 2000 17(1):22 3 10855222
Wellnitz U, Fritz P, Voudouri V, et al The validity of telepathological frozen section diagnosis with ISDN-mediated remote microscopy Virchows Archiv 2000 437(1):52 7 10963380
Wells CA, Sowter C Telepathology: a diagnostic tool for the millennium? J Pathol 2000 191(1):1 7 10767711
Wheeler MF 'Soft wall' technologies coming closer to home Health Manage Technol 1994 15(4):22 4
Whited JD, Hall RP Diagnostic accuracy and precision in assessing dermatologic disease. Problem or promise? Arch Dermatol 1997 133(11):1409 15 9371025
Whited JD, Hall RP, Simel DL, et al Reliability and accuracy of dermatologists' clinic-based and digital image consultations J Am Acad Dermatol 1999 41(5 Pt 1):693 702 10534630
Whited JD, Hall RP, Simel DL, et al Primary care clinicians' performance for detecting actinic keratoses and skin cancer [published erratum appears in Arch Intern Med 1997 Aug 11-25;157(15):1686] Arch Intern Med 1997 157(9):985 90 9140269
Whited JD, Mills BJ, Hall RP, et al A pilot trial of digital imaging in skin cancer J Telemed Telecare 1998 4(2):108 12 9744167
Whitlock WL, Brown A, Moore K, et al Telemedicine improved diabetic management Mil Med 2000 165(8):579 84 10957848
Whitmore SM, Jaffe LB Public perceptions of nurse practitioners [letter] Nurse Pract 1996 21(2):19 20
Whitten P, Collins B Nurse reactions to a prototype home telemedicine system J Telemed Telecare 1998 4(Suppl 1):50 2 9640735
Whitten P, Collins B, Mair F Nurse and patient reactions to a developmental home telecare system J Telemed Telecare 1998 4(3):152 60 10321043
Whitten P, Cook D, Kingsley C, et al School-based telemedicine: teachers', nurses' and administrators' perceptions J Telemed Telecare 2000 6(Suppl 1):S129 32 10793997
Whitten P, Cook DJ, Doolittle G An analysis of provider perceptions for telehospice Am J Hospice Palliative Care 1998 15(5):267 74
Whitten P, Cook DJ, Shaw P, et al Telekid Care: bringing health care into schools Telemed J 1998 4(4):335 43 10220474
Whitten P, Kingsley C, Grigsby J Results of a meta-analysis of cost-benefit research: is this a question worth asking? J Telemed Telecare 2000 6(Suppl 1):S4 6 10793957
Whitten P, Mair F, Collins B Home telenursing in Kansas: patients' perceptions of uses and benefits J Telemed Telecare 1997 3(Suppl 1):67 9 9218390
Whitten P, Sypher BD, Patterson JD, 2nd Transcending the technology of telemedicine: an analysis of telemedicine in North Carolina Health Commun 2000 12(2):109 35 10938909
Wichansky AM Usability testing in 2000 and beyond Ergonomics 2000 43(7):998 1006 10929833
Wiebe S Which systems are really strategic? Journal of Healthc Inf Manage 1998 12(3):7 15
Williams B Health care is online to stay Tenn Medicine 2000 93(5):157 9
Williams RJ Provider survival depends on staff effort Behav Healthc Tomorrow 1999 8(4):26 8 10557692
Wilson LS, Gill RW, Sharp IF, et al Building the Hospital Without Walls-a CSIRO home telecare initiative Telemed J 2000 6(2):275 81 10957741
Windhorst CE, Weaver DM 1999 introduces the virtual audience ... and Y2K fallout Healthc Strategist 1999 3(2):11 2
Winokur TS, McClellan S, Siegal GP, et al A prospective trial of telepathology for intraoperative consultation (frozen sections) Hum Pathol 2000 31(7):781 5 10923912
Wolbransky J, Ho P ATA Conference report. Telemedicine in the new millennium MD Comput 1999 16(4):40 3
Wolf R, Ballan S Virtual doctors-ready for launching Int J Dermatol 2000 39(7):487 9 10940109
Wood FB, Wallingford KT, Siegel ER Transitioning to the Internet: results of a National Library of Medicine user survey Bull Med Libr Assoc 1997 85(4):331 40 226289 9431421
Woods KF, Johnson JA, Kutlar A, et al. Sickle cell disease telemedicine network for rural outreach. J Telemed Telecare. 2000;6:285-290. [pmid: 11070590].
Woods KF, Kutlar A, Johnson JA, et al Sickle cell telemedicine and standard clinical encounters: a comparison of patient satisfaction Telemed J 1999 5(4):349 56 10908450
Woods KF, Onuoha A, Schade RR, et al Helicobacter pylori infection in sickle cell disease J Natl Med Assoc 2000 92(7):361 5 10946532
Wootton R, Bloomer SE, Corbett R, et al Multicentre randomised control trial comparing real time teledermatology with conventional outpatient dermatological care: societal cost-benefit analysis BMJ 2000 320(7244):1252 6 27370 10797038
Wootton R, Loane M, Mair F, et al The potential for telemedicine in home nursing J Telemed Telecare 1998 4(4):214 8 10505357
Wootton R, McKelvey A, McNicholl B, et al Transfer of telemedical support to Cornwall from a national telemedicine network during a solar eclipse J Telemed Telecare 2000 6(Suppl 1):S182 6 10794014
Work M, Mackevicius NK Information systems' key role in healthcare change J Healthc Resource Manage 1995 13(1):23 6
Worth ER, Patrick TB. Do electronic mail discussion lists act as virtual colleagues?. Proc AMIA Ann Fall Symposium. 1997:325-9.
Wright D, Chestnutt L Telemedicine in the twenty-first century-report of a workshop [letter] J Telemed Telecare 2000 6(2):120 3 10824382
Xu Y, Sauquet D, Zapletal E, et al. The "mediator service", a component to ease the integration of medical applications in the SynEx framework. Stud Health Technol Inform. 1999;68:768-73. [pmid: 10724998].
Yamamoto H What works. Swedish Medical Center website attracts $50,000 a month in referrals Health Manage Technol 1999 20(3):44 5
Yamamoto LG, Ash KM, Boychuk RB, et al Personal computer teleradiology interhospital image transmission of neonatal radto facilitate tertiary neonatology telephone consultation and patient transfer J Perinatol 1996 16(4):292 8 8866301
Yamamoto LG, Williams DR A demonstration of instant pocket wireless CT teleradiology to facilitate stat neurosurgical consultation and future telemedicine implications Am J Emerg Med 2000 18(4):423 6 10919531
Yamauchi K, Ikeda M, Ota Y, et al Evaluation of the Space Collaboration System: its history, image quality and effectiveness for joint case conference Nagoya J Med Sci 2000 63(1-2):19 24 10911717
Yearwood J, Pham B Case-based support in a cooperative medical diagnosis environment Telemed J 2000 6(2):243 50 10957737
Yellowlees P Trauma debriefing by telemedicine J Telemed Telecare 1998 4(4):239 40 10505361
Yellowlees PM Intelligent health systems and third millennium medicine in Australia [editorial] Telemed J 2000 6(2):197 200 10957730
Yellowlees PM, Brooks PM Health online: the future isn't what it used to be Med J Aust 1999 171(10):522 5 10816700
Yogesan K, Constable IJ, Barry CJ, et al Telemedicine screening of diabetic retinopathy using a hand-held fundus camera Telemed J 2000 6(2):219 23 10957734
Yogesan K, Constable IJ, Morgan W, et al International transmission of tele-ophthalmology images J Telemed Telecare 2000 6(1):41 4 10824390
Yogesan K, Cuypers M, Barry CJ, et al Tele-ophthalmology screening for retinal and anterior segment diseases J Telemed Telecare 2000 6(Suppl 1):S96 8 10793986
Yom SS The Internet and the future of minority health JAMA 1996 275(9):
Yoong A, Das S, Carroll S, et al A national survey to assess current use of computerised information systems in obstetrics Br J Obstet Gynaecol 1993 100(3):205 8 8476823
Yousem DM, Beauchamp NJ, Jr Clinical input into designing a PACS J Digit Imaging 2000 13(1):19 24 10696597
Zabalgoitia M, Ismaeil M Diagnostic and prognostic use of stress echo in acute coronary syndromes including emergency department imaging Echocardiography 2000 17(5):479 93 10979025
Zablocki E A new resource: empowered patients Qual Let Healthc Lead 1998 10(8):2 10
Zajtchuk R, Gilbert GR Telemedicine: a new dimension in the practice of medicine Dis Mon 1999 45(6):197 262 10484993
Zaylor C, Whitten P, Kingsley C Telemedicine services to a county jail J Telemed Telecare 2000 6(Suppl 1):S93 5 10793985
Zelingher J Administrative chores? Internet to the rescue: [news] MD Comput 1996 13(5):380 2, 385-7 8824098
Zhang J, Stahl JN, Huang HK, et al Real-time teleconsultation with high-resolution and large-volume medical images for collaborative healthcare IEEE Trans Inf Technol Biomed 2000 4(2):178 85 10866418
Zheng LM, Sone S, Itani Y, et al Effect of CT digital image compression on detection of coronary artery calcification Acta Radiol 2000 41(2):116 21 10741781
Zhou J, Hogarth MA, Walters RF, et al Hybrid system for telepathology Hum Pathol 2000 31(7):829 33 10923920
Ziegler J. Private matters, public good. State of Health Care in America. 1997.
Zigelman MD Health care information technology a primitive affair Phys Exec 2000 26(1):37 8