# References

1 Hersh WR, Wallace JA, Patterson PK, et al. Telemedicine for the medicare population. Evidence Report/Technology Assessment No. 24 (prepared by the Oregon Health Sciences University Evidence-based Practice Center under Contract No. 290-97-0018). AHRQ Publication No. 01-E012. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
2 Chesnut R, Carney N, Maynard H, et al. Rehabilitation for Traumatic Brain Injury. Evidence report no. 2 (Contract 290-97-0018 to Oregon Health Sciences University). Rockville, MD: Agency for Health Care Policy and Research; 1999.
3 Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnostic tests JAMA 1999 282(11):1061 6 10493205
4 Egglin TK, Feinstein AR Context bias. A problem in diagnostic radiology JAMA 1996 276(21):1752 5 8940325
5 Millman M, editor. Access to Health Care in America. Washington, DC: National Academy Press; 1993.
6 Udvarhelyi IS, Colditz GA, Rai A, et al Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly? Ann Intern Med 1992 116(3):238 44 1530808
7 Gold M, Siegel J, Russell L, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
8 Patterson S, Botchway C Dental screenings using telehealth technology: a pilot study J Can Dent Assoc 1998 64(11):806 10 9879146
9 Schwartz SD, Harrison SA, Ferrone PJ, et al Telemedical evaluation and management of retinopathy of prematurity using a fiberoptic digital fundus camera Ophthalmology 2000 107(1):25 8 10647714
10 Yamamoto LG, Ash KM, Boychuk RB, et al Personal computer teleradiology interhospital image transmission of neonatal radiographs to facilitate tertiary neonatology telephone consultation and patient transfer J Perinatol 1996 16(4):292 8 8866301
11 Miyasaka K, Suzuki Y, Sakai H, et al Interactive communication in high-technology home care: videophones for pediatric ventilatory care Pediatrics 1997 99(1):
12 Marrero DG, Vandagriff JL, Kronz K, et al Using telecommunication technology to manage children with diabetes: the Computer-Linked Outpatient Clinic (CLOC) Study Diabetes Educ 1995 21(4):313 9 7621734
13 Gray JE, Safran C, Davis RB, et al Baby care link: Using the Internet and telemedicine to improve care for high-risk infants Pediatrics 2000 106(6):1318 24 11099583
14 di Biase N, Napoli A, Sabbatini A, et al Telemedicine in the treatment of diabetic pregnancy Ann Ist Super Sanita 1997 33(3):347 51 9542261
15 Frost D, Beischer W Telemedicine in the management of pregnancy in type 1 diabetic women [letter] Diabetes Care 2000 23(6):863 4 10841015
16 Cartwright W, Dalton K, Swindells H, et al. Objective measurement of anxiety in hypertensive pregnant women managed in hospital and in the community. Br J Obstet Gynaecol. 1992;99:182-5. [pmid: 1606113].
17 Dawson A, Cohen D, Candelier C, et al Domiciliary midwifery support in high-risk pregnancy incorporating telephonic fetal heart rate monitoring: a health technology randomized assessment J Telemed Telecare 1999 5(4):220 30 10829372
18 Torok M, Turi Z, Kovacs F Ten years' clinical experience with telemedicine in prenatal care in Hungary J Telemed Telecare 1999 5(Suppl 1):S14 7
19 Flatley-Brennan P Computer network home care demonstration: a randomized trial in persons living with AIDS Comput Biol Med 1998 28(5):489 508 9861507
20 Brennan PF, Moore SA, Smyth KA The effects of a special computer network on caregivers of persons with Alzheimer's disease Nurs Res 1995 44(3):166 72 7761293
21 Gustafson DH, Hawkins R, Boberg E, et al Impact of a patient-centered, computer-based health information/support system Am J Prev Med 1999 16(1):1 9
22 Kofos D, Pitetti R, Orr R, et al Telemedicine in pediatric transport: a feasibility study Pediatrics 1998 102(5):
23 Elford R, White H, Bowering R, et al A randomized, controlled trial of child psychiatric assessments conducted using videoconferencing J Telemed Telecare 2000 6(2):73 82 10824374
24 Belmont JM, Mattioli LF, Goertz KK, et al Evaluation of remote stethoscopy for pediatric telecardiology Telemed J 1995 1(2):133 49 10165332
25 Casey F, Brown D, Craig BG, et al Diagnosis of neonatal congenital heart defects by remote consultation using a low-cost telemedicine link J Telemed Telecare 1996 2(3):165 9 9375052
26 Casey F, Brown D, Corrigan N, et al Value of a low-cost telemedicine link in the remote echocardiographic diagnosis of congenital heart defects J Telemed Telecare 1998 4(Suppl 1):46 8 9640733
27 Finley JP, Sharratt GP, Nanton MA, et al Paediatric echocardiography by telemedicine-nine years' experience J Telemed Telecare 1997 3(4):200 4 9614734
28 Rendina MC. The effect of telemedicine on neonatal intensive care unit length of stay in very low birthweight infants. Proceedings AMIA Annual Symposium. 1998:111-5.
29 Rendina MC, Long WA, deBliek R Effect size and experimental power analysis in a paediatric cardiology telemedicine system J Telemed Telecare 1997 3(Suppl 1):56 7 9218385
30 Sable C, Roca T, Gold J, et al Live transmission of neonatal echocardiograms from underserved areas: accuracy, patient care, and cost Telemed J 1999 5(4):339 47 10908449
31 Whitten P, Sypher BD, Patterson JD, 2nd Transcending the technology of telemedicine: an analysis of telemedicine in North Carolina Health Communication 2000 12(2):109 35 10938909
32 Holtan A Patient reactions to specialist telemedicine consultations-a sociological approach J Telemed Telecare 1998 4(4):206 13 10505356
33 Karp WB, Grigsby RK, McSwiggan-Hardin M, et al Use of telemedicine for children with special health care needs Pediatrics 2000 105(4 Pt 1):843 7 10742330
34 Massman NJ, Dodge JD, Fortman KK, et al Burns follow-up: an innovative application of telemedicine J Telemed Telecare 1999 5(Suppl 1):S52 4 10534841
35 Chan FY, Soong B, Lessing K, et al Clinical value of real-time tertiary fetal ultrasound consultation by telemedicine: preliminary evaluation Telemed J 2000 6(2):237 42 10957736
36 Chi CH, Chang I, Wu WP Emergency department-based telemedicine Am J Emerg Med 1999 17(4):408 11 10452445
37 McLaren P, Ball CJ, Summerfield AB, et al An evaluation of the use of interactive television in an acute psychiatric service J Telemed Telecare 1995 1(2):79 85 9375124
38 Stevens A, Milne R, Lilford RJ, et al. How do new technologies get into practice? Keeping pace with new technologies: systems needed to identify and evaluate them. BMJ. 1999;319:1291-5. [pmid: 10559044]. [pmcid: 1129069].
39 Banta HD, Sanes JR Assessing the social impacts of medical technologies J Community Health 1978 3(3):245 58 721958
40 Lilford RJ, Braunholtz DA, Greenhalgh R, et al Trials and fast changing technologies: the case for tracker studies BMJ 2000 320(7226):43 6 10617532 1117318