# Conclusions and Future Research

This supplemental report covering the areas of pediatrics, obstetrics, and indirect-clinician home telemedicine echoes the findings of our initial report for the Medicare domain, which is that while the use of telemedicine is small but growing, the evidence for its efficacy is incomplete. Many of the studies are small and/or methodologically limited, so it cannot be determined whether telemedicine is efficacious.

In the new clinical areas, we found few studies in store-and-forward telemedicine. There is modest evidence of benefit in diagnosis and management decisions from the areas of pediatric dental screening, pediatric ophthalmology, and neonatalogy.

In self-monitoring/testing telemedicine for the areas of pediatrics, obstetrics, and clinician-indirect home telemedicine, there is evidence that access to care can be improved when patients and families have the opportunity to receive telehealth care at home rather than in-person care in a clinic or hospital. Access is particularly enhanced when the telehealth system enables timely communication between patients or families and care providers that allows self-management and necessary adjustments that may prevent hospitalization. There is some evidence that this form of telemedicine improves health outcomes, but the study sample sizes are usually small, and even when they are not, the treatment effects are small.

There is also some evidence for the efficacy of clinician-interactive telemedicine, but the studies do not clearly define which technologies provide benefit or cost-efficiency. Some promising areas for diagnosis included emergency medicine, psychiatry, and cardiology. Most of the studies measuring access to care provide evidence that it is improved. Although none of these studies were randomized controlled trials, they provide moderately strong evidence of access improvement over prior conditions. Clinician-interactive telemedicine was the only area for which any cost studies were found. The three cost studies did not adequately demonstrate that telemedicine reduces costs of care (except comparing only selected costs). No study addressed cost-effectiveness.

In interpreting these results, it is important to recognize the possibility of publication bias, whereby studies with negative results may be less likely to be published. Because of the heterogeneous studies in the data we have uncovered, we cannot assess whether such a bias is present. We do know that many programs have not published efficacy data, but we cannot determine whether this is due to failure to collect data or failure to publish it.

## Gaps in Research

Numerous gaps remain in the research on the efficacy of telemedicine. The problem is not that studies have strong evidence against efficacy, but rather that their methodologies preclude definitive statements. Many of them have small sample sizes that limit statistical power. Others are done in settings that may not generalize to real clinical settings. Most include convenience samples of patients rather than target populations that might benefit most from improved access to health services, such as those who are indigent and/or have complex chronic diseases.

While these gaps underscore the importance of scientific validation, they do not diminish the case for developing telemedicine. It is important that these gaps be closed by research funded by objective third parties, such as the National Institutes of Health (NIH) and the Agency for Healthcare Research and Quality (AHRQ).

In the peer-reviewed literature as well as other media reports, we found a preponderance of observational studies evaluating active telemedicine programs. Active programs demonstrate that the technology can be made operational and, in some cases, may be clinically and economically viable. The longevity of these programs, however, is not clear, and many may fail to survive beyond initial funding or enthusiasm. Lack of information about the viability of these programs limits the generalizability of these studies reviewed for this supplemental report.

Another gap in research is that many studies are not focused on the patients who stand to gain the most from the availability of telemedicine services. It may well be that telemedicine studies in the somewhat artificial experimental conditions set up in outpatient clinics, emergency rooms, and nursing homes would have different results in actual underserved rural or inner city locations. This is because the research goals of most evaluations are often limited to proving the feasibility of implementing new technology. As McLaren and Ball wrote in 1995,

(Telemedicine's) driving force has been developments in communications technology, and as new communications systems are developed health applications are proposed such as supporting the delivery of primary health care to geographically remote areas or regions underserved through the maldistribution of professional expertise. Despite rapid technological advances, evaluations of such systems have been largely superficial, and more thorough evaluations have failed to show significant advantages for more advanced and expensive technology over older technology such as the telephone. Methods for evaluating the impact of particular technologies on the health care system need to be developed and clearer benefits shown in terms of improved standards of care.^37^

This pattern is not unique to telemedicine. Frequently, when new technologies are introduced into practice, they are introduced "without a clear idea of which patients will benefit most, what the balance of benefits and harms is, and what value for money technologies offer."^38^ To close these information gaps, specific hypotheses concerning a target population, methods of implementation, and effects on access to care, resource use, and health outcomes must be the driving force in research.

These gaps in information limit the ability of policymakers to make informed judgments about telemedicine coverage. This is particularly problematic if the decision to provide reimbursement for a particular service depends on having high-quality evidence that the benefits outweigh the harms and that the service is cost-effective. For many services, we found no reliable evidence about clinical effectiveness, harms, or cost-effectiveness.

## Priorities for Future Research

Prioritizing research needs is an important, early step in evaluating telemedicine. Some criteria for prioritizing effectiveness research are listed below. Programs with high research priority should:

- Address common, serious clinical conditions that require frequent contact with the health care system and often place a heavy burden on patients or their parents and caregivers that limits the effectiveness of care. In some specialties, such as pediatrics and obstetrics, covered in this report, there are fewer practitioners in rural areas (proportionally to internal medicine or family medicine), so telemedicine may be able to provide additional primary care.
- Address clinical procedures and circumstances for which components of care can be performed remotely. Examples include inexpensive home otoscopes that allow assessment of ear pain in children, home fetal monitoring in pregnant women, store-and-forward teleradiology and telepathology, home health care delivered by a parent or nurse, frequent review of laboratory parameters, and revision of management (e.g., medication use) in patients with chronic conditions.
- Aim to reduce medical errors in diagnosis or management.
- Extend the capacity of the health care system to provide care to populations for whom barriers to access have been shown to affect indicators of health outcome and quality of care.
- Promote other policy goals, such as strengthening rural health care by keeping care local.
- Priority-setting for effectiveness studies should also consider the degree of uncertainty about benefits, harms, and costs, and the likelihood that the research will have an impact.

Also in future research, economic evaluations need to focus on episodes of diseases or conditions rather than a single interaction with the health care system. In addition, such evaluations need to focus on societal and patient perspectives. They also need to focus on meaningful outcomes (such as quality-adjusted life-years), should include adverse events, and should incorporate indirect costs associated with travel (that may be reduced with telemedicine applications). These recommendations are described in more detail in the original report.^1^

## Need for Experimental Designs and Registry Methods

The need for randomized controlled trials to establish the effectiveness of new technologies is widely accepted.^39^ Well-done trials can ensure early adoption of techniques that are clearly cost-effective and early detection of problems that need to be corrected. Large, inclusive, observational studies that measure the effect of providing a service on population-based measures of utilization, access, and outcomes are also important because they provide information about how a particular service performs in actual practice. These designs, properly reviewed by experienced investigators in study sections, offer a higher potential to provide high-quality information about effectiveness than do demonstration projects.

There are differing opinions about the role and timing of randomized controlled trials in evaluating the efficacy of telemedicine. Some caution against starting trials too early, before they have had time to detect and address system problems or an effective implementation strategy. Others note that, by the time a randomized trial is designed and funded, not to mention completed, the targeted intervention may already have changed substantially.

While designing studies of emerging technologies is not simple, it can be accomplished. In fact, evaluating the clinical impact of a telemedicine service beginning with the first patients it is used for has several advantages. First, starting a registry or trial when technology is still changing "ensures maximum use of information after it has stabilized."^40^ Second, when technical performance and operator skill are important component of effectiveness, they are part of the intervention and should be studied. Such a design prevents selective reporting of only the best results of a given application, a bias that is a common flaw in existing studies. Over time, a registry containing all clinicians who provide these services, and all patients who use them, can provide important data about the evolution of the technique and about the "learning curve" for clinicians who might want to adopt the service in their practices.

The fact that telemedicine is evolving thus heightens the need to assess its impact systematically. Telemedicine is an ideal topic for innovative experimental designs that are adapted to rapidly changing technologies. Recently, techniques to adapt randomized trial design to rapidly changing interventions have been proposed. For example, a "tracker trial" is guided by flexible protocols and offers the opportunity to add or drop arms as clinically available options for delivering a service emerge and others become obsolete.^40^ The use of this approach, or other innovative approaches to studying technologies that change rapidly, should be incorporated into future research about telemedicine.

## Basic Research to Inform Telemedicine

Along with telecommunication technology itself, the characteristics of the patients studied and the judgment of an individual physician, often a specialist, are major components of the clinical intervention in telemedicine. The results of an evaluation will be more generalizable to other patients and to clinicians in other settings if the characteristics of the patient population are defined and the judgments of the study physicians are consistent and reproducible. Most studies have focused on recruitment of participating clinicians rather than on identifying a target patient population, selected because of the potential to improve outcomes via better access to care.

From the viewpoint of informatics, then, there is a need for basic research to inform the implementation of telemedicine programs. This research should:

- Refine the target population for telemedicine services. This research should: - Address the burden of disease attributable to poor access to specialty care. - Evaluate barriers to access that coincide with (and might affect the impact of telemedicine services on) distance and mobility barriers. - Identify groups that are most likely to benefit from specific telemedicine services. Clinical studies should examine differences in effectiveness and cost-effectiveness based on the circumstances of the use of telemedicine. The research should examine the relationship between the effectiveness of telemedicine services and characteristics, - Establish valid measures of access that allow relevant indicators to be quantified, e.g. hours or days saved by patients, additional encounters made possible with telemedicine, miles saved with telemedicine per encounter. Health needs, and barriers to access of rural poor, inner-city poor, and other populations.
- Refine clinical interventions prompted by telemedicine services. This research should: - Develop and validate protocols, including computer-assisted decision tools, to use self-monitoring and testing information effectively in reducing preventable hospitalizations and improving functional outcomes. - Examine strategies for organizing telemedicine services in a way that reduces the burden on participating practitioners. Specifically, we recommend developing a request for proposals to explore ways to implement telemedicine services in the context of community-based primary care practices. This can be best accomplished by conducting this research in association with primary care practice networks. In the past, most telemedicine research involving a referring primary care physician has used small convenience samples of clinicians. Primary care practice networks are the "laboratory" for conducting research about practice management, for designing research that minimizes the disruption to the flow of practice, and for examining the context and effects of innovative services in community-based practice settings.
- Develop or adapt standardized tools to measure the effectiveness and harms of telemedicine services.
- Explore different mechanisms for delivery and payment for telemedicine services, assessing their impact on utilization in a target population of patients.

## Other Recommendations for Research

Editors of scientific journals might also play a role in improving the quality of studies that evaluate telemedicine technology. The telemedicine literature we reviewed, whether in core or clinical specialty journals, is riddled with studies that describe creative uses of technology but feature a low-quality evaluation study. We recommend that journal editors decline to publish these low-quality evaluations and instead let the technologists publish their technology descriptions and allow their technology-assessment collaborators to carry out appropriate evaluations.

## Conclusions on Future Research

A large number of gaps remain in both efficacy and effectiveness research concerning access, satisfaction, quality of care, cost, and cost-effectiveness of telemedicine applications. The body of current knowledge surveyed in this supplemental review provides sufficient evidence that new, better-designed studies need to be undertaken. With the availability of telemedicine programs throughout the United States expanding rapidly, the demand for the technology has already begun to grow, even without compelling evidence to demonstrate its efficacy or cost-effectiveness. This leaves the policymakers with the difficult question of how to deal with this growing field. Given that demand, it seems equally compelling that some significant resources should be expended proposing, funding, designing, implementing, and reporting on this intriguing question.