# Results

This chapter presents the results of the literature review followed by identification and evaluation of the evidence. The results are organized into three major sections by study area -- store-and-forward, self-monitoring/testing, and clinician-interactive services. Each of these sections then covers the five key questions as they relate to that study area. Finally, within each question, the clinical domains (pediatrics, obstetrics, and clinician-indirect home telemedicine) are discussed.

## Results of the Systematic Review

Through the abstract review process, we selected 122 studies as possibly eligible. We then retrieved the full-text articles for these studies. For papers excluded from this systematic review, the reviewers were asked to judge their relevance for inclusion in an update to the original telemedicine evidence review -- that is, telemedicine interventions relevant to a Medicare population. This designation was catalogued to provide a method to update the original report at a later date.

In addition, papers that had been identified but excluded from the original report (e.g., wrong subject population or clinical domain) were re-reviewed for inclusion in the supplemental report. Fourteen papers identified from the original search strategy and time period were found to have applicable evidence for the supplemental report. These studies were added to the 122 for a total of 136 papers retrieved for full-text review.

The 136 papers meeting initial inclusion criteria were reviewed by four members of the research team (WRH, PKP, DK, WPN) for relevance to their assigned key questions. After a second round of inclusion/exclusion criteria, 28 studies^1^ were included in this systematic review. Some studies addressed more than one key question. There were a total of seven studies that addressed diagnosis and management, 23 that assessed access to care, 10 that looked at health outcomes, three that measured satisfaction, and three that evaluated cost. The distribution into the three telemedicine areas is shown in Table 4.

1 The two papers by Rendina et al. are considered one study.

Table 4. Included articles for each of the key questions for the three study areas

| Diagnosis and management | Access | Outcomes | Satisfaction | Cost
Store-and-forward | 3 | 1 | 0 | 0 | 0
Self-monitoring/testing | 0 | 11 | 9 | 1 | 0
Clinician-interactive | 4 | 11 | 1 | 2 | 3
TOTALS | 7 | 23 | 10 | 3 | 3

## Store-and-Forward Telemedicine

### Key Question 1. Does store-and-forward telemedicine result in comparable diagnosis and appropriateness of recommendations for management?

We identified three studies that assessed diagnosis and/or management in store-and-forward telemedicine versus face-to-face care in pediatrics (Evidence Table 1). The first was a study of dental screening in children that compared the agreement of dentists with their recommendations made in-person and via patient history and imaging three months later. The rate of agreement on the presence of decay was modest (kappa = 0.50-0.58), but was high (kappa = 0.93-1.0) for management decisions on extraction and fillings.^8^ A major limitation of this study was that the evaluating dentists were the same for the in-person and telemedicine evaluation.

A second study compared diagnostic and management agreement in pediatric ophthalmology, assessing 19 eyes in 10 patients. Agreement was high for diagnosis (89-95 percent) but lower for management plans (42 percent).^9^ A limitation of this study was the lack of measurement of agreement in examiners using the same modality. A third study, in neonatology, found that neonatologists having access to chest radiographs via telemedicine had a higher rate of accuracy in identifying findings than the in-person general pediatrician.^10^ A problem with this study was present in all three, which was the small number of physicians used.

### Key Question 2. Does the availability of store-and-forward telemedicine provide comparable access to care?

The dental study by Patterson,^8^ described above, demonstrated 100 percent improved access to experts in dental screening for school children and validated that telehealth screening compared favorably with the traditional method of visual inspection by dental hygenists or assistants. Although telehealth did not reduce travel, it did improve access to a higher level of dental expertise.

### Key Question 3. Does store-and-forward telemedicine result in comparable health outcomes?

No studies assessed health outcomes for store-and-forward telemedicine in pediatrics or obstetrics.

### Key Question 4. Does store-and-forward telemedicine result in comparable patient or clinician satisfaction with care?

No studies addressed patient or clinician satisfaction with store-and-forward telemedicine in pediatrics or obstetrics.

### Key Question 5. Does store-and-forward telemedicine result in comparable costs of care and/or cost-effectiveness?

No studies of store-and-forward telemedicine addressed issues of cost or cost-effectiveness in pediatrics or obstetrics.

## Self-Monitoring/Testing Telemedicine

### Key Question 1. Does self-monitoring/testing telemedicine result in comparable diagnosis and appropriateness of recommendations for management?

No studies assessed diagnosis and/or management in self-monitoring/testing telemedicine in pediatrics, obstetrics, or clinician-indirect home telemedicine.

### Key Question 2. Does the availability of self-monitoring/testing telemedicine provide comparable access to care?

Increasingly, self-monitoring/testing telemedicine applications are being tested for the purposes of improving self-care and disease management. Evidence of access to care could be gleaned from three pediatrics studies, five obstetrics studies, and three studies regarding the use of clinician-indirect home telemedicine (Evidence Table 3).

The three pediatric studies that evaluated self-monitoring/testing telehealth interventions provided evidence of improved access. In Japan, a "near-television quality" home digital videophone system was used to provide respiratory specialist communication with families of 10 children at home.^11^ The system was deployed between a pediatric intensive care unit, patient homes, and technical (ventilation) advisors for the purpose of providing specialty care support directly to patients. The impact of this observational study on access to care could be interpreted from findings of fewer clinic visits and hospital days required by patients following installation of home videophones, thereby achieving longer periods of comparable care that did not require family travel. A randomized controlled trial (RCT) of children with diabetes compared those who used an electronic glycemic data transmittal system at home with those who did not.^12^ Subjects in both groups had clinic visits every three months, so there was no opportunity to compare family travel requirements. However, experimental subjects had improved access to nursing guidance for insulin adjustment and other alterations following each data transmittal between clinic visits. Another RCT evaluated a system of Internet communication between a neonatal intensive care unit (NICU) and patient homes.^13^ Access was comparable between the study groups, as determined by the frequency of family telephone calls and visits to the NICU. However, when the whole episode of neonatal care was taken into account, access was improved for experimental families, since 20 percent of control patients needed additional hospitalization following NICU discharge versus zero percent for the experimental group.

In obstetrics, two controlled studies^14, 15^ evaluated electronic monitoring systems designed to help diabetic patients maintain good glycemic control and reduce the incidence and severity of complications associated with pregnancy. Both studies had relatively small samples, but they provided evidence of greater access via telehealth with more timely metabolic management advice. In one, an RCT,^14^ both groups regularly monitored their blood glucose at home, but experimental subjects had 24-hour access to electronic insulin adjustment decisionmaking support, while control subjects relied on this type of help from a nurse who visited approximately weekly. Although experimental subjects saw the nurse only every 2-4 weeks, they were more satisfied with their access to professional help. The other trial^15^ was not an RCT, and staff saw patients in the clinic rather than at home. Both studies found that telehealth subjects needed less frequent contact with clinicians than control subjects. Thus, evidence of improved access was based on increased guidance availability (24-hour) for experimental subjects^14^ and increased home care and decreased clinic care for experimental subjects in both studies.

Three other obstetrics studies, all RCTs, provided positive evidence of improved access with telehealth self-monitoring systems at home. An RCT by Cartwright et al.^16^ compared blood pressure monitoring at home versus in the hospital and demonstrated that home monitoring improved access because it reduced travel and other barriers associated with hospital admission. An RCT by Dawson and colleagues^17^ compared fetal monitoring at home versus in a hospital or clinic for high-risk patients, and both experimental and control subjects had access to visits at home and in the clinic. Telehealth subjects demonstrated they had improved access because they received more care at home and less care in clinic or hospital than conventional care subjects did. A multi-center RCT of uterine contraction monitoring in Hungary^18^ also demonstrated that telehealth has the potential of improved access over traditional care because it can be done at home instead of in the clinic or hospital, although few details were provided.

Three RCTs provided evidence of increased access to care via the use of clinician-indirect home telemedicine.^19-21^ These studies evaluated informational and support programs that utilized a keyboard and computer network and were developed for use by caregivers of persons with Alzheimer Disease, persons living with AIDS, and persons who were HIV-positive. Evidence of improved access to care was strong in the Flatley-Brennan studies,^19, 20^ since access was the independent (experimental) variable that was assessed. In addition, the frequency of system use was also reported, with experimental subjects using it an average of twice per week over a one-year period. In the Gustafson et al. study,^21^ evidence of access was comparable, since there were no differences in the use of outpatient care and emergency care for experimental and control groups. The study showed evidence of improved access because experimental subjects made more phone calls to providers during the experiment, there were fewer hospitalizations, and they had fewer hospital days per subject.

### Key Question 3. Does self-monitoring/testing telemedicine result in comparable health outcomes?

We identified nine studies that assessed health outcomes in the self-monitoring/testing category: three each from pediatrics, obstetrics, and clinician-indirect home telemedicine (Evidence Table 4). The three pediatrics studies already noted to address access also assessed health outcomes. The first study, using videophones for pediatric home ventilator patients, found that the number of unscheduled hospital visits and hospital admission days was reduced significantly compared with historical controls.^11^ A study of computer-linked home blood sugar monitoring showed no difference in glycemic control between groups (HgbA1C for both groups actually rose), emergency room visits, psychological status, and family functioning.^12^ The study of an Internet-based telemedicine program for families of children in a neonatal intensive care unit found that among infants born with weight of <1,000 grams, there was a trend towards shorter hospital stays.^13^

Three of the five studies addressing access from obstetrics also looked at health outcomes. Both studies of home diabetic monitoring found improvements in blood sugar values but not in HgbA1C, although each had very small sample sizes and probable inadequate statistical power to detect a difference.^14, 15^ The study of hypertension found that an at-home blood pressure monitoring system resulted in comparable levels of blood pressure, anxiety, and gestational age of delivery as hospital-based monitoring.^16^

The three clinician-indirect home telemedicine studies demonstrated a variety of improved health outcomes, such as improved patient decision-making confidence, ^19, 20^ and decreased hospitalizations. ^21^ Each system provided a variety of functions, including online information and support groups, the latter with some monitoring by a health care professional. All the studies showed improvement in the health outcomes they set out to measure.

### Key Question 4. Does self-monitoring/testing telemedicine result in comparable patient or clinician satisfaction with care?

One self-monitoring/testing study dealt with satisfaction (Evidence Table 5). The study of the Internet-based telemedicine program for families of children in a neonatal intensive care unit, mentioned in the section above, also addressed satisfaction in self-monitoring/testing telemedicine, taken from the viewpoint of the family.^13^ The Picker Institute Neonatal Intensive Care Unit Family Satisfaction Survey was administered 1-4 months after NICU discharge. The study group scored significantly higher (p<.05) on scales measuring perceived quality of care and environment/visitation policies. Differences were not significant in the six other areas, although the study group scored higher in four of these.

### Key Question 5. Does self-monitoring/testing telemedicine result in comparable costs of care and/or cost-effectiveness?

We identified no studies of self-monitoring/testing telemedicine that addressed issues of cost or cost-effectiveness in the subject areas for this report.

## Clinician-Interactive Telemedicine

### Key Question 1. Does clinician-interactive telemedicine result in comparable diagnosis and appropriateness of recommendations for management?

We identified four studies that addressed diagnosis and management, all in pediatrics, from the specialties of emergency medicine, psychiatry, and cardiology (Evidence Table 6). In the study of emergency medicine, 15 patients had assessment of their physical examination findings by both an in-person emergency room physician (gold standard) and a pediatric critical care specialist via telemedicine.^22^ The sensitivity and specificity of the telemedicine examinations in detecting abnormal findings was 87.5 percent and 93.0 percent respectively. In the study of child psychiatry, 23 patients had diagnostic and management plans developed via in-person and telemedicine examinations.^23^ There was agreement among examiners in all but one patient (96 percent).

One of the cardiology studies assessed pediatric stethoscopy. A total of 116 patients were assessed for diagnostic agreement among cardiologists using acoustic, electronic, and tele-electronic stethoscopes, with the acoustic considered the gold standard.^24^ The kappa scores for agreement with the acoustic stethoscope and the others were 0.64-0.65, while the sensitivity and specificity in the need for echocardiogram or followup were 88 percent and 97 percent respectively.

In the second cardiology study, 10 neonates suspected of having congenital heart disease were first examined via a telemedicine link and then examined in followup by a pediatric cardiologist.^25^ Of nine patients who were actually assessed, the correct diagnosis was obtainable via the telemedicine link.

### Key Question 2. Does the availability of clinician-interactive telemedicine provide comparable access to care?

In pediatrics, ten studies, published in 11 papers, met the inclusion criteria for this telemedicine mode (Evidence Table 7). Five of these studies evaluated electronic transmittal of echocardiogram data with live telemedicine guidance and interpretation from cardiologists,^25-30^ and all but one^27^ were conducted with neonatal samples. A study by Rendina et al.^28, 29^ used a quasi-control design with pre- and post-intervention samples of six-month periods to compare access differences. Two access measures, length of hospital stay resulting in more home care and less hospital care as well as rate of patient transfer to care 2 hours from home, showed non-significant but decreased access to treatment, which can be considered comparable access to care.

Non-experimental designs were also used to demonstrate improved access to care in pediatric cardiology studies. Three^25, 26, 30^ demonstrated improved access to local screening for neonatal abnormal heart conditions by experts, and improved access to local treatment rather than transfer to a distant tertiary care center. Although the determination of negated transfer was based on unvalidated diagnostic differences between consultant and local provider, rather than on validated diagnostic differences, the comparison of experimental and control subjects, or pre-post sample incidence rates, these findings nevertheless provided positive evidence of access improvement.

In one study of cardiology telemedicine consultation for newborns and older children,^27^ patient transfers were prevented for 28 percent of a non-emergency sample. Although some echograms were repeated (19 percent) and diagnostic agreement was 81 percent, there was no discussion of how transfer judgments were made or validated. Thus, it was difficult to determine whether telehealth was the predictive factor for local care and improved access.

Another pediatric study demonstrated the use of telehealth in schools for medical consultation.^31^ Although access was not a central question in this study, the total number of consultations represented 100 percent improved access to medical expertise from inner-city school sites, since there were no consultations prior to the intervention.

Three teleconsultation studies in pediatrics demonstrated improved access to specialist care in remote geographic areas.^32-34^ Although these were not controlled studies, they demonstrated that the telehealth innovation provided 100 percent more local care than the prior method of travelling to a tertiary care center, and two studies measured the number of travel miles saved per patient. In Minnesota, patients from 15 sites participated in a study of burn specialist followup care via telemedicine.^34^ Evidence of 100 percent improved access to care is based on findings that nearly 700 miles of travel were saved per patient. Another type of need that has traditionally been met in large medical centers is for consultation regarding rare genetic disorders and neurological conditions. In Georgia, provision of this type of distance consultation resulted in saved travel of 89 miles per patient. Finally, a qualitative demonstration study showed that adult patients and parents of pediatric patients who were willing to try telehealth for otolaryngology consultation felt they had access to more information with image visualization and more opportunity for informed communication with physicians than they did prior to telehealth.

In obstetrics, two papers met the inclusion criteria for this telemedicine mode. Researchers in Australia,^35^ where distances between tertiary care and primary care are great, evaluated a system of real-time ultrasound transmission for diagnosis and assessment. Maternal-fetal medicine subspecialists provided consultation and a few patients (12 percent) would have been transferred a great distance (1,500 kilometers) for specialty care if it were not for telemedicine. Although this was a non-controlled pilot study with a small sample size, it provided modest evidence of improved access with the intervention. In Taiwan, where emergency department physicians provided consultation to remote islanders, teleconsultation also improved access (32 percent of the whole sample) with reduced transfers to tertiary care.^36^ However, the rate of improved access for the few obstetric patients was not reported.

### Key Question 3. Does clinician-interactive telemedicine result in comparable health outcomes?

We identified one study that assessed health outcomes of clinician-interactive telemedicine in the neonatology domain (Evidence Table 8).^28, 29^ This retrospective analysis controlling for known risk factors found that infants who had telemedicine consultations also had a reduced length of stay.

### Key Question 4. Does clinician-interactive telemedicine result in comparable patient or clinician satisfaction with care?

No studies addressed satisfaction in the area of obstetrics. Only two studies that addressed patient satisfaction with clinician-interactive telemedicine in pediatrics were identified (Evidence Table 9). The first^23^ was a cross-over study conducted in a convenience sample of 22 children referred for outpatient mental health assessments. Patients were randomized to receive an initial evaluation by telemedicine or a face-to-face encounter. This was followed the next day by an evaluation with a different child psychiatrist using the other modality. No significant differences were noted between face-to-face sessions and video-conferencing. Ninety-one percent of parents reported they would prefer telemedicine to long travel for a face-to-face session. The second study^33^ was conducted in children with special health care needs. In this study, telemedicine visits were used to augment face-to-face visits at remote clinics by the same pediatric subspecialty staff. There were 127 of 141 caregivers (90 percent response rate) who completed the Client Satisfaction Questionnaire with very positive results (Likert scores 3.7-3.8 out of 4) on items addressing quality of service, meeting patient needs, and willingness to use telemedicine again.

The same two studies were also the only ones identified that addressed clinician attitudes or satisfaction with this modality. In response to an unvalidated questionnaire, child psychiatrists indicated a significant preference for face-to-face interviews.^23^ However, videoconferencing was viewed as an "acceptable" alternative and did not interfere with diagnosis. This study is compromised by a small sample size (n=5) and the fact that the psychiatrists served as their own controls. Attitudes of pediatric subspecialists toward telemedicine were reported in the second study.^33^ On an unvalidated survey, 70 percent reported positive attitudes toward telemedicine regarding its feasibility in providing patient consultations and improving access for patients; 44 percent felt it was cost-effective, and 48 percent time-effective. An increase in experience with telemedicine was correlated with more positive responses (r=.3); (p<.05). However, only 14 of the 56 respondents actually participated in the telemedicine sessions, and there are no specific satisfaction data available for this group.

### Key Question 5. Does clinician-interactive telemedicine result in comparable costs of care and/or cost-effectiveness?

Three studies of telemedicine applications in pediatric cardiology addressed this key question (Evidence Table 10). Two reports by Rendina et al. (one study), already described for other key questions, evaluated the use of telemedicine in a neonatal intensive care unit in North Carolina.^28, 29^ This non-randomized (before and after implementation of telemedicine) study found a statistically non-significant reduction of 5.4 days in length of stay (p=0.2) in a selected population (31 patients excluded) with a potential for large cost savings for relatively low cost of the application. Costs were not applied to the various outcome measures so no comparison of total cost for episodes of care is possible. Assuming constant rates of use of the telemedicine application, recruiting all patients over a 12-year period would be needed to achieve adequate statistical power to demonstrate a significant difference in length of stay in this clinical setting. Thus, a large multi-center study would be needed to fully assess the potential for savings in length of stay.

The Finley et al. study^27^ assessing real-time echocardiography for regional hospitals in Canada found that for over 2 years, the costs of emergency room and clinic visits avoided by those using the telemedicine application would have exceeded the cost of the telemedicine application. These authors compared diagnosis by the telemedicine application and diagnosis by clinic visits for 26 cases and found no "important discrepancies" in diagnosis. However, the lack of clinical outcomes (the episode of care or all care over a specified time period) and the small number of cases compared (with low statistical power to detect a difference in diagnostic accuracy) make it difficult to draw conclusions.

The previously described study by Sable et al.^30^ demonstrated that reduction in the number of helicopter transports could offset the costs associated with a telemedicine application. They also report that charges for echocardiography interpretation and for inpatient care of transported patients were greater during the period when telemedicine was used than during a previous period of equal duration. However, since the number of patients and severity of conditions are not reported and since no data on patients not transported are provided, interpretation of these results is problematic.