# Methods

This chapter describes the methods the research team used to identify and analyze the telemedicine literature for the supplemental domains of pediatrics, obstetrics, and clinician-indirect home telemedicine in the three study areas and to summarize the scientific evidence for effectiveness and cost.

## Literature Search

We searched for peer-reviewed literature using several bibliographic databases. In addition, we conducted hand searches of leading telemedicine journals and identified key papers from the reference lists of journal articles.

For our original evidence report on telemedicine for the Medicare population, we designed a search to find any publications about telemedicine and used it to search the MEDLINE, CINAHL, and HealthSTAR databases through January 2000 (Appendix A). Through this process, we captured studies of pediatric, obstetric, and clinician-indirect home telemedicine; however, they were excluded from the original report since they were outside its scope. For this supplemental report, we reviewed our original search results and identified studies relevant to this report. In addition, we ran the same searches on MEDLINE, CINAHL, and HealthSTAR covering November 1999 to December 2000, which produced 1,035 citations not previously identified. We identified 41 additional studies from the reference lists of included papers, and 58 separate articles from hand searching two peer-reviewed telemedicine publications, the Journal of Telemedicine and Telecare and Telemedicine Journal, to make a total of 1,172 studies for our initial review.

## Selection of Abstracts and Retrieval of Full-text Articles

The results of the literature search and selection of articles for inclusion are shown in Figure 3. For the 1,172 papers identified by the search, reference lists, or hand searches, two teams of two reviewers (WRH and JAW, PKP and JAW) conducted independent screening reviews of all citation titles and abstracts retrieved. The reviewers read citation abstracts (or titles only, if the abstract was not available) to make inclusion decisions for subsequent full-text review. A third reviewer (either WRH or PKP), who was blinded to previous reviewers' results, made "tiebreaker" decisions for citations about which the pairs disagreed.

Figure 3. Literature search tree and results

The inclusion criteria for this review were 1) that the study be relevant to at least one of the three study areas; 2) that it address at least one key question in the analytic framework for that study area; and 3) that it contain reported results (i.e., "data"). Studies that assessed a clinical service that did not require face-to-face encounters (e.g., radiology or pathology diagnosis) were excluded.

For the store-and-forward study area, we included studies that used store-and-forward techniques as well as studies that used systems that could be easily adaptable to store-and-forward. We excluded reports of telephone care programs. We also excluded studies of services that provided medical advice directly to the public -- e.g., Internet-based models with no direct or indirect telecommunications contact with a medical provider.

## Data Abstraction

For each key question, data from each included study were abstracted by an assigned single reviewer, using paper or electronic abstraction forms, and entered into an electronic database. The information abstracted for each study varied by the key question addressed. For studies of diagnostic performance, we recorded the reference standard and whatever measure in the paper reported its efficacy. Additional variables that were abstracted for studies of the economic impact of telemedicine activities included the type of economic study, types of comparisons, data sources, cost unit, discount rate, sensitivity analysis parameters, program expansion capability, and generalizability of the program.

## Assessment of Study Quality

We critically appraised the included studies for each study area and key question and discussed the strengths and limitations of the most important studies at weekly meetings of the research team. Studies that examined the effect of telemedicine activities on clinical outcomes, patient satisfaction, or access to care were rated for quality according to the scale shown in Table 1.^2^ The optimal design for studies of diagnostic tests differs from the optimal design for studies of therapies. For this reason, we used a separate scale to rate the quality of studies that compared the accuracy of "telediagnosis" to diagnosis made in conventional clinical encounters (Table 2). We also abstracted features of the study design that were likely to be associated with bias in studies of diagnostic test performance.^3, 4^ These quality grading criteria are the same as those used in the previous evidence report.

Table 1. Classification of evidence for studies of therapy and monitoring

| Study Class | Characteristic
Strength of evidence
Strength of evidence | I | Properly designed random controlled trials Random controlled trials that contain design flaws preventing specification of Class I Properly designed trials with control groups not randomized Multi-center or population-based longitudinal (cohort) study Case control studies Descriptive studies (uncontrolled case series) Clinical experience Expert opinion Case reports
Strength of evidence | II | Random controlled trials that contain design flaws preventing specification of Class I Properly designed trials with control groups not randomized Multi-center or population-based longitudinal (cohort) study Case control studies
Strength of evidence | III | Descriptive studies (uncontrolled case series) Clinical experience Expert opinion Case reports
Direction of effect
Direction of effect | A | Strong positive effect
Direction of effect | B | Weak positive effect
Direction of effect | C | Conflicting evidence for effect
Direction of effect | D | Negative effect (evidence that the technology is inferior or ineffective)

Table 2. Classification of evidence for diagnostic studies

Study Class | Characteristic
I | Case series of consecutive patients from relevant population of individuals who would use telemedicine; using an objective gold standard with blinded interpretation of results; with inter-observer analysis
II | Case series of patients from relevant population of individuals who would use telemedicine; using an objective gold standard
III | Case series not from relevant population or not using appropriate methodology for diagnostic test evaluation

We applied the following additional criteria to studies addressing access to care and economic analyses.

### Access to Care

In appraising studies of access to care, we employed the Institute of Medicine (IOM) model of access to care,^5^ which incorporates four types of indicators: barriers (structural, financial, and personal); utilization; mediators (treatment effectiveness, provider quality, and patient adherence); and outcomes, including health status (e.g., mortality, well-being, or functionality) and equity of services among various populations. The IOM strongly recommended that studies of access to care measure both utilization and outcomes. Also, when access to an improved level of care was the experimental condition, compared with the control group that did not have the same level of access, we considered the experimental group as having 100 percent improved access. Although improved access was inherent in the study design in these instances, we interpreted it as demonstrating improved access feasibility.

### Economic Analyses

The economic evaluation of the telemedicine applications from the literature review included both cost studies and cost-consequence studies. Economic evaluation is a more encompassing term than cost-effectiveness analysis, which refers to a particular class of economic assessments in which costs are compared to measures of effectiveness (such as life-years). Economic assessments encompass other study designs, including program-cost analyses and cost-of-illness studies. Program-cost analyses review only the cost of implementation and maintenance of a particular application. The other designs (including cost-effectiveness studies) are cost-consequence studies, which compare the costs to other consequences, including other economic consequences (as the costs averted by the application), technical consequences (as images of the same quality), or health outcomes (as length of stay or life-years).

Since the literature was limited, studies were not excluded based on reporting costs versus charges. Perspective and study design were summarized for studies evaluated based on how they were described in the articles. Economic evaluations of populations specific to these clinical domains were included -- e.g., pediatric cardiography. We excluded economic analyses of telemedicine applications in prisons because the costs of transporting prisoners are not relevant to these clinical domains. We also excluded reports that claimed to report program costs but which had incomplete data or only a single summary cost, such as only the total cost to set up a telemedicine application.

To appraise economic evaluations, we applied six principles (Table 3) that were advanced in a previous review of the quality of published cost-effectiveness analyses.^6^ These principles provide a straightforward way of assessing the quality of economic evaluations, and are consistent with the guidelines for conducting economic evaluations outlined by the Panel on Cost-effectiveness convened by the U.S. Public Health Service in 1993.^7^

Table 3. Summary of six principles for economic evaluations^6^

Principle | Description
Perspective stated | Whose costs and consequences are considered?
Benefit described | What are non-economic consequences of program?
Costs included | Describe intervention costs, morbidity or side effect costs, averted costs and induced costs?
Discounting included | Are future costs and consequences adjusted for timing?
Sensitivity analyses | For values that are uncertain (e.g. assumed), are analyses performed using alternative values?
Cost-effectiveness ratios stated | Are alternatives compared in a way that allows decisions on prioritization to be made?

## Data Synthesis and Identification of Information Gaps

We reported our data synthesis in a summary that represents the state of knowledge for telemedicine in practice for these specific three study areas and three clinical domains. For the synthesis, we began with the evidence found in a systematic review of telemedicine research. Results of the systematic review are presented in Evidence Tables 1-10. The reviewer for each key question constructed separate evidence tables for each of the three study areas (store-and-forward, self-monitoring/testing, and clinician-interactive). In general, the evidence tables include author/date, key research question(s), study design/level, population, sample/selection, measures, results, quality rating, and limitations.

We also developed recommendations for research to address telemedicine knowledge gaps. To match these gaps with the capabilities of specific research methods, we classified the telemedicine services according to the type of evidence that would be needed to determine whether the specific goals of covering such services had been met. We emphasized the relationship between the type and level of evidence found in the systematic review of effectiveness and the types of studies that might be funded to address the gaps in knowledge in this growing field of research.