# Introduction

This report is a supplement to an earlier evidence report, Telemedicine for the Medicare Population,^1^ which was intended to help policymakers weigh the evidence relevant to coverage of telemedicine services under Medicare. That report focused on telemedicine programs and clinical settings that had been used with or were likely to be applied to Medicare beneficiaries. As we prepared that report, it became apparent that there are also telemedicine studies among non-Medicare beneficiaries -- e.g., children and pregnant women -- that could inform policymakers and provide more comprehensive evidence of the state of the science regarding telemedicine applications. In addition, the first evidence report only partially included a class of telemedicine applications in which the beneficiary used a home computer or modem-driven telephone system to either report information or access information and support from Internet resources and indirectly interact with a clinician. Self-monitoring/testing applications in the first report required direct interaction with a clinician

## Goal of the Report

The goal of this report is to systematically review the evidence in the clinical areas of pediatric and obstetric telemedicine as well as home-based telemedicine where there is indirect involvement of the health care professional. (In this report, we will refer to the latter as clinician-indirect home telemedicine.) Specifically, the report summarizes scientific evidence on the diagnostic accuracy, access, clinical outcomes, satisfaction, and cost-effectiveness of services provided by telemedicine technologies for these patient groups. It also identifies gaps in the evidence and makes recommendations for evaluating telemedicine services for these populations in the future.

For the purpose of continuity, the report format is similar to that of the prior telemedicine evidence report. This chapter contains definitions of the telemedicine services covered by this report and our key questions. Chapter 2 describes the methods used in the evidence review process. Chapter 3 presents the results for studies that met the inclusion criteria for this evidence review. The evidence is clustered according to three categories of telemedicine service defined in our original report: store-and-forward, self-monitoring/testing, and clinician-interactive services. Chapter 4 provides conclusions and recommendations for future research.

## Definitions

Telemedicine is the use of telecommunications technology for medical diagnostic, monitoring, and therapeutic purposes when distance separates the participants. Some descriptions use the broader term telehealth to indicate care beyond that provided by medical doctors -- for example, its use for patient-to-patient or caregiver-to-caregiver communication. Other descriptions use narrower terms focused on medical specialties, such as telenursing, telecardiology, or telepsychiatry. A telemedicine encounter is the event where clinical services are provided using telemedicine. The narrower term teleconsultation is used when a traditional specialist medical consultation is performed using telemedicine.

The three clinical practice areas reviewed in this report are defined as follows. The term pediatric applies to any telemedicine study in which the sample consisted wholly or partially of persons aged 18 or younger, including studies with neonatal samples. The term obstetric applies to any telemedicine study in which the sample consisted entirely of women seeking pregnancy-related care. The term clinician-indirect home telemedicine applies to home-based telemedicine (called self-monitoring/testing in our original report) where a telemedicine application used in the home has only indirect involvement by the health care professional. This form of telemedicine was studied for all patient populations in this report. This was different from other study areas in this report, which were assessed only for the pediatric and obstetric populations.

## Telemedicine Study Areas

As with the previous report, we reviewed three categories of telemedicine services: store-and-forward, self-monitoring/testing, and clinician-interactive services. Likewise, we also excluded services where telemedicine was not a substitute for face-to-face patient care (e.g., radiology and pathology) and where the telemedicine system made exclusive use of audio-only telephone services.

Store-and-forward telemedicine services collect medical data, store them, and then forward them to be interpreted later. This type of service provides the ability to capture and store electronic still or moving images of patients, as well as audio and text data. A store-and-forward system eliminates the need to have the patient and clinician available at the same time. It is usually employed as a clinical medical consultation (as opposed to an office or hospital visit from a medical specialist). The key question associated with store-and-forward use is, Are store-and-forward teleconsultations an acceptable alternative to real-time consultations?

Self-monitoring/testing telemedicine services enable clinicians and others to monitor physiologic measurements, test results, images, and sounds, usually collected in a patient's residence or a nursing facility. Post-acute-care patients, those with chronic illnesses, and patients with conditions that limit their functionality often require close monitoring and followup. These patients may also be taking medications that require testing and/or titration of dosage. Telemedicine systems use a variety of strategies to accomplish this monitoring while reducing the need for face-to-face visits with clinicians that may be inconvenient and costly for the patient and family. For example, some technologies allow patients to directly upload monitoring data to a health care system whereby it can be made available to several clinicians on the patient's health care team. Others make use of higher bandwidth telephone or cable television infrastructures to apply two-way interactive video, audio, and medical diagnostic instrumentation. The close monitoring afforded by these approaches may allow better health care through early detection of problems or more precise dosing of medications and biologic agents, potentially reducing costs. These types of systems also support self-determination and empowerment of patients that can also enhance clinician-patient collaboration.

Clinician-interactive telemedicine services are real-time, clinician-patient interactions that conventionally require face-to-face encounters between a patient and a clinician. Examples of this category include office visits, hospital visits, and consultations, and these may include examinations and procedures conducted during the course of the visits.

Figure 1 shows the decision process for including or excluding studies in this report. All studies passing through these inclusion criteria still had to meet the methodologic inclusion criteria outlined in Chapter 2. Figure 2 shows another view of the coverage of this supplemental report versus the original one, with the pediatric and obstetric areas added to the three telemedicine study areas plus the broadening of self-monitoring/testing telemedicine to include clinician-indirect home telemedicine.

Figure 1. Decision process for including and excluding citations

Figure 2. Clinical coverage areas of supplemental report (shaded) versus original report (not shaded)

## Key Questions about the Efficacy of Telemedicine Services

The key questions that served as a guide for reviewing the literature in the evaluation of pediatric, obstetric, and clinician-indirect home telemedicine applications were derived by consensus among the evidence-review team based on the analytic framework established for the original evidence report. For the current report, the questions were applied to studies in all three practice areas as a whole group within each of the three categories of telemedicine services: store-and-forward; self-monitoring/testing; and clinician-interactive.

The key underlying question was, To what extent does the telemedicine service delivery have the same components as a traditional clinical encounter for that type of service? These components might include a clinical history, which could be comprehensive or problem-focused; an examination; and clinical decisionmaking, which encompasses analyzing clinical data, initiating or validating a diagnosis, and generating or reviewing a management plan. The specific study questions were:

1. Does telemedicine result in comparable diagnosis and appropriateness of recommendations for management?
2. Does the availability of telemedicine provide comparable access to care?
3. Does telemedicine result in comparable health outcomes?
4. Does telemedicine result in comparable patient or clinician satisfaction with care?
5. Does telemedicine result in comparable costs of care and/or cost-effectiveness?

To assess the diagnostic accuracy and effect of these services on management decisions, we looked at the evidence to determine if the telemedicine mode of delivery results in comparable diagnosis and/or appropriate recommendations for management of the patient.

The most powerful evidence for the safety and efficacy of telemedicine applications would directly link their use to comparable health outcomes such as functional status, quality of life, or mortality. In the absence of direct evidence, the effectiveness of telemedicine might be inferred from evidence about improved diagnosis, coordination, or management decisions. To make this inference, evidence should be available that these particular intermediate outcomes are reasonable indicators or proxies for actual health outcomes. For a teledermatology application among children, for example, evidence should be available that more timely or accurate diagnosis of specific skin conditions reduces morbidity or mortality.

Other types of evidence were also sought. One was improved access to care, interpreted as improved convenience, quicker time to urgent or emergent care, or a similar level of care provided in a less intense environment. Another was satisfaction with the telemedicine services, according to patients and/or clinicians. A final type of review of the study findings was to determine whether telemedicine contributes to cost reduction in providing the health services, or whether it can provide added health benefits at a reasonable marginal cost.