# Appendix C. General Comments

Reviewer | Review Section | General and Specific Comments | Disposition
Zollo | C. Methods | Missing critical lit: Citation for Scholz | Article does not address any of our key questions; it is about telemedicine usage.
Zollo | E. Conclusions and Future Research | Long comments not included in e file | No specific suggestions for change in these comments.
Segal | | No specific comments
Lairson | A. Gen Comments | The phrases "modest evidence" and "moderately strong" are used to characterize the evidence. It is not entirely clear what this means and therefore should be defined or more specific language substituted. | These phrases have been replaced with "some evidence."
Lairson | C. Methods | Telematics Application Program, European Commission see the web site http:158.169.50.95:10080/telematics/projectguide/healthcare.html for a list of ongoing projects in Europe. | This site lists ongoing projects but not evaluation studies.
Lairson | D. Results | See page specific comments
Lairson | E. Conclusions and Future Research | Future studies should measure indirect cost consequences associated with telemedicine services. The technology has the potential to save large amounts of patient and family time and this should be valued and included in evaluations done form the societal and patient perspectives. | We agree and have noted this in the report.
Jennett | A. Gen Comments | Excellent report. Important addition to the literature, thorough lit search, well written and researched. Good flow and easily understood. Pertinent information provided.
Tarczy-Hornoch | A. Gen Comments | Please send copies.
Tarczy-Hornoch | A. Gen Comments | The NLM telemedicine projects are under-represented, does not appear that all the data presented at recent NLM evaluate in Telemedicine symposium was incorporated. | The studies presented at the NLM meeting, which the PI attended and have the proceedings for, are mostly preliminary. The short papers in the proceedings have not been peer-reviewed.
Tarczy-Hornoch | E. Conclusions and Future Research | See page 6A and 6B also
Noorani | C. Methods | The Cochrane Library, Issue 4, Oxford Update software (2000). A recent Cochrane review by Correl R, et al on "telemedicine versus face-to-face care: effects on professional practice and health care outcomes". Five (of 7) trials reviews are concerned with the provision of home care or patient self-monitoring of chronic disease. Two of these studies (Cartwright, Marrero) are included in your report. | The other studies in the Cochrane review were not pertinent to this patient population, and were cited in the original Medicare report.
Noorani | D. Results | Considering in titles of labels ?: "clinician-indirect" as opposed to "patient-indirect". Table 7 | The title of the table has been changed to use "clinician-indirect."
Noorani | E. Conclusions and Future Research | Well-written sections on "gaps in research and future directions

Reviewer | Page | Line | Comments | Disposition
| 43 | 8-14 | Discussion about primary care networks. I'm not sure I would agree with this. The resistance to telemedicine is coming from the consultants because they are already way too busy with clinical practice, teaching, research, and publishing to add another area of responsibility to their schedules. PC practitioners and patient and families benefit the most from telemedicine so it is not as difficult to elicit their participation. If you have a PC network as a test bed, who does the consulting? Consultants also need a way to integrate telemedicine into their schedules. | We disagree. Although we acknowledge the resistance from consultants, primary care networks would still be an excellent place to study telemedicine.
Zollo
| 10 | 22 | It's difficult to assess cost effectiveness when there is only minimal reimbursement | We disagree. Reimbursement and cost-effectiveness are two separate issues.
| 18 | 1-7 | As stated previously, it is difficult to assess where the articles included in this study are representative of the published literature w/o being able to review the search strategies used. Many telemedicine articles are being published in non-telemedicine journals, some with a more rigorous peer-review process. | The search strategy was in Appendix I, but this reviewer did not see it. No other reviewers had any comments on it.
| 21 | 9-13 | Did costs include both start-up and ongoing costs? | Yes.
| 42 | 9-11 | "Most studies focused on recruitment of clinicians rather than identify a target patient population..." That's because it is so difficult to recruit consultants to participate and w/out them, you have no teleconsultation process. | True.
Segal | | | No comments
Segal | 10 | 29 | Is vague. Which health outcomes were improved? | The specific improved outcomes are now listed.
Lairson
| 3 | 7 | What does "modest evidence" mean? | We changed this to "some evidence."
| 10 | 10 | What does "modest evidence" mean? | We changed this to "some evidence."
| 10 | 18 | What does "moderately strong evidence" mean? | We changed this to "some evidence."
| 39 | 13 | Remove "ness" from cost-effectiveness | Done.
| 42 | | Add a section on economic evaluation, e.g. incorporate indirect cost savings in economic evaluations done from societal and patient perspectives. | We have added some comments on this.
| Title page | | Evidence-based should be Evidence-Based | Fixed.
Jennett
| 2 | search strategy | Insert "years" which were searched. Was the TIE searched? | We added the years searched. We did not search TIE, whose peer-reviewed evaluation articles are similar to those in the databases we did search.
| 2 | 15 | Add review of progress reports and conference papers from NLM Telemedicine initiative | The studies presented at the NLM meeting, which the PI attended and have the proceedings for, are mostly preliminary. The short papers in the proceedings have not been peer-reviewed.
Tarczy-Hornoch
| 4 | 2 | Consider also especially in Pediatrics and Obstetric interactions of benefit/cost savings for conditions that are very frequent, (I.e. a cheaper home store/forward tele otoscope for otitis media as a screening tool to decrease visits to ER and clinic for rule out otitis) | We use these as examples in the future research section.
| 9 | 12 | See p2, l 15 comment | The studies presented at the NLM meeting, which the PI attended and have the proceedings for, are mostly preliminary. The short papers in the proceedings have not been peer-reviewed.
| 11 | 6 | See p 4, l 2 comments. Also consider funding only studies w/adequate statistical power and encouraging multi-center studies) | We use these as examples in the future research section.
| 36 | | Same comments as above apply to conclusions section and priorities for future research | Agree.
| 39 | 20 | Extremely common but less serious a possible target for pediatrics | We mention this in future research.
| 40 | 5 | In peds and OB total # of practitioners are smaller than IM (ditto for subspecialties). Thus another high yield area would be those subspecialties that are a) capable of delivery telemedicine services and b) more than 200 miles from most common sites of peds and ob care | We mention this in future research.
| 6 | 28,32,37 | Spelling corrections (some other sections also require careful editing (e.g.. Table 7)
Noorani
| 9 | 11 | Journal of Telemedicine and TELECARE, NOW Telemedicine journal and e-health | We prefer to use the names that these journals had when we hand-searched them.
| 9 | 12 | Journal of Telemedicine and TELECARE, NOW Telemedicine journal and e-health | We prefer to use the names that these journals had when we hand-searched them.

Reviewer | General and Specific Comments | Disposition
Zollo | Would like to see search strategy | Search strategy was in Appendix I in her copy but she missed it.
Segal | | No specific comments
Jennett | | No specific comments
Tarczy-Hornoch | | No specific comments
Lairson | | No specific comments
Noorani | Check Table 7 | Legend fixed per general comments.