# Appendix B. Task Order Personnel and Peer Reviewers

## Task Order Personnel

- Principal Investigator:
- William R. Hersh, MD
- Associate Professor and Chief
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- OHSU EPC Director:
- Mark Helfand, MD, MPH
- Associate Professor of Internal Medicine and Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- OHSU EPC Administrator:
- Kathryn Pyle Krages, AMLS, MA
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Research Coordinator:
- James A. Wallace, BA
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Co-investigator:
- Merwyn R. Greenlick, PhD
- Professor and Chair Emeritus
- Department of Public Health and Preventive Medicine
- Oregon Health Sciences University
- Portland, OR

- Co-investigator:
- Patricia K. Patterson, RN, PhD
- Assistant Professor of Nursing and Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Co-investigator:
- Dale F. Kraemer, PhD
- Assistant Professor
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Co-investigator:
- W. Paul Nichol, MD
- Clinical Associate Professor of Medicine
- University of Washington
- Seattle, WA

- Librarian:
- Patty Davies, MS
- Oregon Health Sciences University Library
- Portland, OR

- Technical Writer/Editor:
- Gary Miranda, MA
- Portland, OR

- Administrative Assistant:
- Susan Wingenfeld, BA
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

## Peer Reviewers

- Mark Segal, PhD
- Vice President, Business Development for Governments & Associations
- Medical Present Value, Inc.
- Oak Park, IL

- Peter Tarczey-Hornoch, MD
- Assistant Professor
- Department of Pediatrics
- University of Washington
- Seattle, WA

- Hussein Noorani, MSc
- Research Officer
- Canadian Coordinating Office for Health Technology Assessment
- Ottawa, Ontario
- Canada

- Penny Jennett, MD
- Professor, Faculty of Medicine
- University of Calgary Health Sciences Center
- Calgary, Alberta
- Canada

- Susan Zollo, MA
- Director, Telemedicine Resource Center
- University of Iowa
- Iowa City, IA

- David Lairson, PhD
- Professor of Management & Policy Sciences
- University of Texas - Houston
- Houston, TX