# Appendix A. Literature Search Strategies

## Broad Search Strategy (Medline, HealthStar)

1. exp telemedicine/
2. telemedicine.mp.
3. telehealth.tw.
4. remote consultation$.mp.
5. 1 or 2 or 3 or 4
6. limit 5 to english language
7. 5 not 6
8. limit 7 to abstracts
9. 6 or 8

## Supplemental Search Strategy (Medline, HealthStar)

1. exp telemedicine/
2. telemedicine.mp.
3. telehealth.tw.
4. remote consultation$.mp.
5. 1 or 2 or 3 or 4
6. exp home care services/
7. home nursing/
8. 6 or 7
9. exp therapy, computer-assisted/
10. exp computers/
11. exp computer communication networks/
12. exp medical informatics/
13. exp telecommunications/
14. exp monitoring, physiologic/
15. monitor$.tw.
16. blood glucose self-monitoring/
17. self-examination/
18. self exam$.tw.
19. self monitor$.tw.
20. self test$.tw.
21. 14 or 15 or 16 or 17 or 18 or 19 or 20
22. tele$.tw.
23. (remote or offsite or distance).tw. tw=abstract, title
24. rural population/
25. rural health services/
26. hospitals, rural/
27. rural.tw.
28. 22 or 23 or 24 or 25 or 26 or 27
29. 21 and 28
30. 9 or 10 or 11 or 12 or 13 or 29
31. 8 and 30
32. 31 not 5
33. limit 32 to english language
34. 32 not 33
35. limit 34 to abstracts
36. 33 or 35

## Supplemental Search Strategy (CINAHL)

1. exp computer communication networks
2. patient participation
3. exp consumer satisfaction
4. delivery of health care
5. exp home care services
6. exp home nursing
7. house calls/or housecalls.mp
8. 2 or 3 or 4 or 5 or 6 or 7
9. 1 and 8
10. limit 9 to english language