# Appendixes

Appendix A. Literature Search Strategies

Appendix B. Task Order Personnel and Peer Reviewers

Appendix C. General Comments