# Evidence Tables

Evidence Table 1. Studies of diagnosis and management for store-and-forward telemedicine

Source | Experiment | Gold Standard | Sample | Diagnosis | Management | Comments | Number of Clinicians | Study Class
Dermatology
Krupinski, 1999^ 48 ^ | Diagnostic agreement of store and forward versus in-person exam for consults | In-person exam | 308 pts | 83% concordance between in-person and teledermatology, 84% intradermatologist concordance, 81% interdermatologist concordance | Not assessed | | 8 | I-B
Whited, 1999^ 49 ^ | Diagnostic and management plan agreement of store and forward versus in-person exam | In-person exam | 168 lesions in 129 pts | 54% agreement among clinic examiners versus 41-55% between clinic and teledermatology examiners and 49-55% between teledermatology examiners | 77% agreement among clinic examiners versus 56-77% between clinic and teledermatology examiners and 64-83% between teledermatology examiners | | 5 | I-B
Zelickson, 1997^ 50 ^ | Diagnostic and management plan agreement of store and forward versus in-person exam | In-person exam | 30 conditions in 29 pts | 67% correct diagnosis with history alone, 85% with image alone, and 88% with both | 70% correct treatment plan with history alone, 87% with image alone, and 90% with both | All gold standard diagnoses made by one dermatologist | 6 | II-B
Kvedar, 1997^ 51 ^ | Diagnostic agreement of store and forward versus in-person exam for consults | In-person exam | 121 images in 116 patients | 61-64% agreement between remote and in-person examiners | Not assessed | | 15 | II-B
Whited, 1998^ 52 ^ | Diagnostic agreement of store and forward versus in-person exam for skin tumors | Biopsy | 13 lesions in 12 pts | 74% correct diagnosis for in-person examiner versus 58% for store and forward exam | Not assessed | | 4 | III-C
Otolaryngology
Sclafani, 1999^ 53 ^ | Agreement of otolaryngologists in remote non-interactive video versus store and forward exam | In-person exam | 45 pts | Diagnostic agreement 85% for local versus non-interactive and 64% for local versus store and forward | Not assessed | Real-time telemedicine examination was non-interactive | 5 | II-B
Furukawa, 1998^ 54 ^ | Agreement of remote and local otolaryngologists in laryngoscopy | Interpretation by local ENT | 29 pts | Three ENTs made identical all identical diagnoses with still images and text of history | Not assessed | | 4 | III-B
Outpatient Medicine
Houston, 1999^ 138 ^ | Comparison of diagnosis and treatment plans in store and forward telemedicine versus in-person | In-person exam | 19 pts | Complete agreement on all diagnoses | 93% of in-person consults had additional treatment recommendations, 79% of store and forward had additional treatment recommendations | | Not stated | II-C
Ophthalmology
Marcus, 1998^ 56 ^ | Interactive video diagnosis of eye disease in HIV and diabetes mellitus | In-person exam | 34 eyes of 17 HIV pts, 39 eyes of 20 diabetes mellitus pts | For HIV retinopathy, sensitivity = 83% and specificity = 95%. For DM, unable to classify 46% of glaucoma and 36% of retinopathy due to cataract; poor sensitivity (29-50%) for those that could be assessed | Not assessed | | Not stated | II-C
Wound Healing
Wirthlin, 1998 ^ 57 ^ | Agreement in diagnosis and management of photographed versus directly observed wound healing | In-person exam | 38 wounds in 24 pts | For wound diagnosis items, sensitivity = 0.86 and specificity = 0.72 | For wound management, sensitivity = .87 and specificity = .78 | Compared agreement of remote and on-site as well | | II-B

Evidence Table 2. Studies of cost for all studyareas Part 1 - Study overview

Source | Technology | Specialty | Quality Score | Country | Study Type | Perspective | Comparisons | Primary Outcome
Johnston, 2000^ 77 ^ | SM&T | Home Health | <3 of 5 | US (CA) | RCT/cost benefit | Provider (infer) | Home health with and without video connection and diagnostic equipment | Costs of care, satisfaction, others
Bergmo, 1997^ 119 ^ | CIT | Otolaryngology | <4 of 6 | Norway | Cost minimization | Societal (patient and healthcare system) | Teleconsult, specialist visit, referral | Image quality and costs
Burgiss, 1997^ 120 ^ | CIT | Dermatology | 1 of 5 | US (TN) | Program cost analysis | Provider (infer) | Pre/post teledermatology | Cost of care
Loane, 1999^61, 121^ | CIT | Dermatology | 0 of 5 | Ireland | RCT | None | Teledermatology consult vs. office consult | Various resource units
Loane, 2000^ 62 ^ | CIT, S&F | Dermatology | <2 of 5 | Ireland | RCT/cost-benefit | Society (infer) | Teledermatology consult vs. office consult | Societal costs
Wootton, 2000^ 109 ^ | CIT | Dermatology | 4 of 5 | Ireland | RCT/cost-benefit | Society | Teledermatology consult vs. office consult | Societal costs
Doze, 1999^ 116 ^ | CIT | Psychiatry | <2 of 6 | Canada (Alberta) | Program cost analysis | Provider (infer) | Description of pilot study | Operational cost
Doolittle, 1997^ 122 ^ | CIT | Oncology | 1 of 5 | US (KA) | Program cost analysis | Provider (infer) | Telemedicine, specialist fly-in, referral | Costs/pt
Mahmud, 1995^ 72 ^ | SM&T | General medicine | 0 of 6 | US (MN) | Descriptive | None | Anecdotal | Various
Stoeger, 1996^ 124 ^ | CIT | Radiology | <3 of 5 | Austria | Program cost analysis | Provider (infer) | Teleradiology, by car, patient transfer | Cost of care
Darkins, 1996^ 139 ^ | CIT | Emergency med | <1 of 5 | Ireland | Pre/post comparison | Case series | Pre/post urgent care | Referral rates
Maass, 1999^ 126 ^ | CIT | Neuroradiology | <2 of 5 | Finland | Averted costs | Provider (infer) | Description of teleconsult transport costs averted | Averted transport costs
Eljamel, 1992^ 103 ^ | CIT | Radiolology | <2 of 5 | Ireland | Case series | Provider (infer) | More appropriate transport with teleconsult | Image consult "outcomes"
Bailes, 1997^ 101 ^ | CIT | Neurosurgery | <2 of 5 | US (PA) | Program cost analysis | Provider (infer) | Teleconsult with neurosurgeon, implied transport | Cost of care
Armstrong, 1997^ 127 ^ | CIT | Radiology | <1 of 6 | UK (Scotland) | Case series | Case series | Descriptive only | "Quality score"
Zelickson, 1997^ 50 ^ | S&F | Dermatology | <2 of 5 | US (MN) | Program cost analysis | Provider (infer) | Teledermatology vs consult (office or nursing home) | Diagnostic and treatment plan agreement, cost
Halvorsen, 1996^ 140 ^ | S&F | Radiology | 4 of 5 | Norway | Cost minimization | Societal (limited) | Teleradiology, outpost, referral | Total costs
Reid, 1998^ 66 ^ | S&F | Radiology & dermatology | 0 of 5 | Canada (Nova Scotia) | Descriptive | Provider (infer) | Teledermatology and teleradiology | Satisfaction (dermatology) and agreement (radiology)
Friedman, 1996^ 76 ^ | SM&T | Hypertension monitoring | <3 of 5 | US (MA) | RCT | Provider (infer) | Telecommunications monitoring vs. usual care | Mm DBP and compliance
Cameron, 1998^ 123 ^ | CIT | General | <3 of 6 | US (WV) | Simulation model | Society (infer) | Video teleconsult vs. usual care | Cost of care

Evidence Table 2. Part 2 - Cost analysis details

Source | Cost Data Sources | Cost Accounting Sources Included | Cost Unit | Discount Rate (base case) | Results | Sensitivity Analyses | Capability | Generalizability
Johnston, 2000^ 77 ^ | Administrative data? (costs) | Equipment, communication, personnel, travel | US $ | NA | Total costs similar to two arms | None | Can expand | Unclear
Bergmo, 1997^ 119 ^ | National rates (costs) | Equipment, communication, personnel, travel | Norwegian Kr | 5% | Depends on patient volume | Only 1 parameter | Unclear | Improves GP
Burgiss, 1997^ 120 ^ | Medical records (costs/charges) | NA (charges only) | US $ | None | Costs: teledermatology<pre-teledermatology | Only follow-up visit | Unclear | Likely
Loane, 1999^61, 121^ | None | NA (patient time and travel only) | NA | NA | Costs: teledermatology less time for patients more for staff | None | Unclear | Unclear
Loane, 2000^ 62 ^ | Patient forms/average cost accounting | NA (no cost details provided) | NA | NA | Real time - effective/expensive, S&F ineffective | Real time cost differences may be reduced | Can expand | Likely
Wootton, 2000^ 109 ^ | Patient forms/average cost accounting | Equipment, communication, personnel, travel | NA | NA | Teledermatology more costly, but other factors may reduce | Cost differences may be reduced | Can expand | Likely
Doze, 1999^ 116 ^ | Pilot study administrative data (costs) | Equipment, communication, personnel, travel | Canadian $ | NA | Costs similar to visiting psychiatrist | None | Yes | Likely
Doolittle, 1997^ 122 ^ | Equipment and staff (costs) | Equipment, maintenance, communication, personnel, office space | US $ | NA | Costs: referral<telemedicine<fly-in specialist | None | Undemonstrated | Limited
Mahmud, 1995^ 72 ^ | Equipment and visit (charges) | NA (charges only) | US $ | none | Lower cost of video visit than home health visit | None | Unclear | Especially for patients who see MD often
Stoeger, 1996^ 124 ^ | 121 teleradiology consults (costs) | Communication | German Deutsch marks | NA | Teleradiology faster at higher cost than courier | Costs only | Unclear | Likely
Darkins, 1996^ 139 ^ | Equipment and staff (costs) | Equipment, communication, personnel | British pounds | NA | Rarely used, adequate | None | Can expand | Likely
Maass, 1999^ 126 ^ | Patient records (costs/charges) | NA (transport and specialist charges only) | Finland, | NA | Transport costs averted of 42,100 ECU | None | Unclear | Unclear
Eljamel, 1992^ 103 ^ | Unspecified | NA (only total cost savings) | British pounds | NA | Teleconsult improves appropriate transport | None | Likely can expand | Likely
Bailes, 1997^ 101 ^ | Local data (charges) | NA (room and transport charges) | US $ | NA | Neurosurgery teleconsult saved over transport all | None | Unclear | Likely
Armstrong, 1997^ 127 ^ | Unspecified | NA (only total cost savings) | British pounds | NA | Image quality adequate to excellent | None | Can expand | Likely
Zelickson, 1997^ 50 ^ | 30 sample cases (costs/charges) | Equipment, personnel, travel | US $ | NA | Reasonable accuracy, lower costs | None | Unclear | Likely
Halvorsen, 1996^ 140 ^ | Medical records (costs) | Equipment, communication, personnel, travel, office space | British pounds | NA | Costs: outpost<referral<telemedicine | Costs only | Undemonstrated | Limited
Reid, 1998^ 66 ^ | Only summary cost (costs) | Equipment, communication, personnel | Canadian $ | NA | Cost description for teledermatology; no data for teleradiology | None | Unclear | Unclear
Friedman, 1996^ 76 ^ | Expected operating costs (costs) | Equipment, maintenance, communication, personnel, office space | US $ | NA | Cost per %-compliance and per mm-DBP are low | None | Unclear | Likely
Cameron, 1998^ 123 ^ | National data, expert opinion, local data (costs/charges) | NA (charges only) | US $ | None | Given adequate patient volume, telemedicine application will save costs | Only breakeven calculation | Unclear | Unclear

Evidence Table 2. Part 3 - Quality criteria

Source | Perspective Stated | Program Benefit Described | Intervention Costs Included | Morbidity/SE Costs Included | Averted Costs Included | Induced Costs Included | Costs/Benefits Discounted | Sensitivity Analyses | C/E Ratio Estimated
Johnston, 2000^ 77 ^ | N (provider) | Y | Y | Y | Y | Y | NA | N | N
Bergmo, 1997^ 119 ^ | Y (societal?) | Y (transport) | Y | N | Y (only referral) | N | NA | Y (limited) | N
Burgiss, 1997^ 120 ^ | N | N | Y | N | N | N | NA | N | NA
Loane, 1999^ 61 ^ | N (societal) | N | N | N | N | N | NA | N | N
Loane, 2000^62, 121^ | N (societal) | Y | N | N | N | N | NA | Y | N
Wootton, 2000^ 109 ^ | N (societal) | Y | Y | N | Y | Y | NA | Y | N
Doze, 1999^ 116 ^ | N (provider) | Anecdotal | Y | N | Y (transport only) | N | N | N | N
Doolittle, 1997^ 122 ^ | N | N | Y | N | N | N | NA | N | N
Mahmud, 1995^ 72 ^ | N | N | N | N | N | N | N | N | N
Stoeger, 1996^ 124 ^ | N (provider) | Y (transport) | Y | N | N | N | NA | Y (cost only) | N
Darkins, 1996^ 139 ^ | N | N | Y (remote only) | N | N | N | NA | N | N
Maass, 1999^ 126 ^ | N (provider) | Y (transport) | N | N | Y (transport) | N | NA | N | N
Eljamel, 1992^ 103 ^ | N | Y | N | N | Y (transport only) | N | NA | None | N
Bailes, 1997^ 101 ^ | N (provider) | Y (transport) | Y | N | Y (transport only) | N | NA | N | N
Armstrong, 1997^ 127 ^ | N | N | N | N | Y (transport only) | N | N | N | N
Zelickson, 1997^ 50 ^ | N (provider) | Y (dx and rx agreement) | Y | N | N | N | NA | N | N
Halvorsen, 1996^ 140 ^ | Y (societal) | Y (assumed =) | Y | N | Y (travel only) | N | NA | Y (cost only) | N
Reid, 1998^ 66 ^ | N (provider) | N | N | N | N | N | NA | N | N
Friedman, 1996^ 76 ^ | N (provider) | Y (mm-DBP/compliance) | Y | N | N | N | NA | N | Y
Cameron, 1998^ 123 ^ | N (societal) | Y (transport) | Y (model) | N | Y (transport and hospital charge) | N | N | N (breakeven only) | N

Evidence Table 2. Part 4 - Satisfaction and comments

Source | Satisfaction | Comments
Johnston, 2000^ 77 ^ | Y | Higher home health care costs, lower inpatient, outpatient and total care costs (last category not aggregated by authors); home health and non-inpatient costs $63 per patient lower for intervention arm, total costs (with inpatient) $916 lower for intervention arm; abstract indicates indirect costs also considered but not reported, no information on time on study, cost effectiveness (as life year or even hospital days) may show intervention is cost-effective.
Burgiss, 1997^ 120 ^ | NA | Average duration & cost lower using teledermatology service, used charges not costs, little cost breakdown, no standard deviations, outcomes not studied, inaccurate diagnosis not studied
Loane, 1999^61, 121^ | NA | Very poor, what happened after initial visit unclear, follow-up visits should be included and attributed to group initially assigned (not as-treated), no costs assigned only units of resource utilization, lack of separation of follow-up from initial visits, potential response rate bias (much lower in teledermatology group)
Loane, 2000^ 62 ^ | NA | Very poor, what happened after initial visit unclear, follow-up visits should be included and attributed to group initially assigned (not as-treated), no costs assigned only units of resource utilization, lack of separation of follow-up from initial visits, potential response rate bias (much lower in teledermatology group)
Wootton, 2000^ 109 ^ | NA | Very poor, what happened after initial visit unclear, follow-up visits should be included and attributed to group initially assigned (not as-treated), no costs assigned only units of resource utilization, lack of separation of follow-up from initial visits, potential response rate bias (much lower in teledermatology group)
Doze, 1999^ 116 ^ | Y (extensive) | Limited by phone access problems, breakeven analysis of number of visits and cost compared to visiting psychiatrist, ignored costs (as implementation and training), other potential benefits outlined, high satisfaction by pts, providers, etc.; no patient outcomes, no sensitivity analysis (even for phone costs which are variable).
Doolittle, 1997^ 122 ^ | NA | Potential bias-who received which service, no outcomes, poorly itemized costs
Mahmud, 1995^ 72 ^ | Anecdotal | Author from manufacturer (?), pilot study, only anecdotal evidence, no cost of intervention, no outcomes, no comparisons, took less time, cost per month ~$350 for unit alone plus nurse's time
Stoeger, 1997^ 124 ^ | NA | Technical staff costs assumed equal (unlikely if this is only reason for technical staff), no patient outcomes, imputed costs of by-courier and transport-patient options
Darkins, 1996^ 139 ^ | NA | Total referrals down (12%=>3.8%) but only .5% used telemed, no outcomes (only referrals), no data on those w/out telemed post, nurses learn
Maass, 1999^ 126 ^ | NA | Described transport costs for patients with teleconsult, no telemedicine set-up costs reported, actual patient data, 12 of 16 patients transported required immediate surgery, no other patient outcomes (length of stay, discharge status or total costs) reported although likely available in records.
Eljamel, 1992^ 103 ^ | NA | No cost detail, all likely hematomas transferred (if fit for transport) so data discusses only non-hematomas, retrospective pre-post comparison should have been possible, only transport costs compared to teleradiology costs
Bailes, 1997^ 101 ^ | NA | Savings over transport all, comparison group only mentioned (no sample size, etc.) so assume all transport w/out neurosurgical teleencounter no patient outcomes (modeled estimated length of stay and total charges)
Armstrong, 1997^ 127 ^ | "Good" | Only 1 cost described, cost of system not given, other costs ignored, no outcomes, only 3% of patients used telepresence
Zelickson, 1997^ 50 ^ | Y (23% of sample) | Diagnosis and treatment agreement reasonable, 5 incorrect diagnoses and 4 incorrect treatment plans, no outcome data (as adverse events), unknown if onsite consults ever wrong, serious statistical flaw as 2 or 3 reviews of same case treated as independent, teledermatology only hypothetical based on images
Halvorsen, 1996^ 140 ^ | NA | Sensitive to leisure time value, patient time needs valuation, potential only, no actual telemedicine service (only what if), reviewed medical records to see which patients could have used telemedicine.
Reid, 1998^ 66 ^ | Y (teledermatology only) | No detailed cost analyses (only one summary measure for teledermatology)
Friedman, 1996^ 76 ^ | Y | Relatively low cost per mm-DBP and % compliance changes, no comparisons of cost-effectiveness to other hypertension inventions, no patient outcomes, can limit service to non-adherent patients to gain most of cost-effectiveness
Cameron, 1998^ 123 ^ | NA | Simulation study used as example of simulation approach, assumed only averted costs are patient transfers, patient travel and family productivity (ignores other costs of episode of care), no reliable estimates of change in access to care, cite data that average cost of stay (across all diagnoses) at remote hospital is about 74% of cost of stay at central hospital (ignores outcomes; is case-mix adjusted at DRG level only), simulation approach needed as no telemedicine applications operating at full capacity/steady state (suggests technology too immature?)

Evidence Table 3. Studies of diagnosis and management for self-monitoring/testing

Source | Domain | Experiment | Gold Standard | Sample | Diagnosis | Management | Comments | Number of Clinicians | Study Class
Finkelstein, 1993^ 68 ^ | Pulmonary | Reliability of home spirometry | Spirometry lab measure | 18 pts | Percent differences average <3% | Not assessed | | Not stated | I-A
Bruderman, 1997^ 69 ^ | Pulmonary | Telespirometry to detect early signs of asthma deterioration | Decision to dispatch mobile ICU | 39 pts | Spirometric data correlated with decision for mobile ICU dispatch 56% of time | Not assessed | | Not stated | II-C
Wirthlin, 1998^ 57 ^ | Surgery | Agreement in diagnosis and management of photographed versus directly observed wound healing | In-person exam | 38 wounds in 24 pts | For wound diagnosis items, sensitivity = 0.86 and specificity = 0.72 | For wound management, sensitivity = .87 and specificity = .78 | Compared agreement of remote and on-site as well | Not stated | II-B

Evidence Table 4. Studies of access for self-monitoring/testing

Source | Purpose | Design | | | Subjects | | Results | Limitations
| | Study Class, Description | Intervention | Control | Population | Sample
Rissam, 1998^ 141 ^ | Assess role of trans-telephonic electro-cardiography in evaluation of cardiac symptoms | III, descriptive | Patient wears cardiac beeper, when symptomatic, placed beeper & electrodes on self & recorded own ECG, then dialed phone to transmit ECG; technician & cardiologist response team 24 hrs for triage decisions | Compared time of symptom onset to call in another study | Post-CABG, post-AMI, post-PTCA, chest pain, angina, palpitations, arrhythmias, PPM/AICD, all ages | n = 664 symptomatic calls | Average time of symptom onset to call = 30 min (compared with 44 min; Roth, 1995) | Comparison group not described; no evidence of relationship between patient condition and time of symptom onset to call; no evidence of care availability impact on outcomes
Mahmud, 1995^ 72 ^ | Evaluate home care, ER, hospital & NH utilization & medication compliance | III, case series, prospective | Telenursing using 2-way video camera + ancillary lens, BP & pulse monitors & stethoscope for image/data transmittal via analog telephone line from pt's home to nurse station or home | None | Managed care pts disabled or chronically impaired | n = 12 Telenursing users (pts) | n = 12 pts (100%) had on-demand face-to-face video access with nurse n = 8 (67%) had more home care without added in-person visits n = 4 (33%) avoided days in hospital, nursing home, or clinic | No comparison group; small sample without selection specification; results are estimated from case descriptions, not frequencies; reduced home care may have been a natural occurrence independent of the intervention

Evidence Table 5. Studies of health outcomes for self-monitoring/testing

Source | Domain | Question | Control | Sample | Results | Comments | Class
Intermediate outcomes
Ahring1992^ 73 ^ | DM | Home blood sugar monitoring RCT | Paper diary | 42 pts | Computer group had HgbA1c drop from 10.6% to 9.2% (13.2%); control group from 11.2% to 10.2% (8.9%) | Not statistically significant, possibly due to low statistical power | II(a)-B
Billiard, 1991^ 74 ^ | DM | Home blood sugar monitoring RCT | Paper diary | 11 pairs of pts in crossover design | Computer group had HgbA1c drop from 6.7% to 6.0%; control group from 6.8% to 6.7% | Difference statistically significant but magnitude small | II(a)-B
Schultz, 1992^ 75 ^ | DM | Home blood sugar monitoring RCT | Paper diary | 20 pts | Reduced HgbA1c levels in computer group but details not given | Claim of statistical significance but no numbers are given | II(a)-B
Friedman, 1996^ 76 ^ | HTN | Automated pt monitoring and counseling RCT | Usual care | 267 pts | Adherence and diastolic BP improved | | I-A
Actual outcomes
Johnston. 2000^ 77 ^ | General Medicine | Home telecare in chronic disease for frail elderly RCT | Home care ? remote video | 212 pts | Comparable medication compliance, knowledge of disease and ability for self-care | | I-B
Nakamura,^ 78 ^ | General Medicine | Home telecare in chronic disease for frail elderly | Home health care without videophone | 32 pts | Improvement in activities of daily living, communication, and at social cognition | Control group different from experimental group | II(b)-B
Mahmud, 1995^ 72 ^ | General Medicine | Home telecare in chronic disease for frail elderly | None | 12 pts | Improved compliance and control of disease process; decreased hospitalization and nursing home placement | No statistics | III-B
Sparks, 1993^ 80 ^ | General Medicine | Comparison of home exercise program with transtelephonic exercise monitoring vs. hospital-based program RCT | Hospital-based program | 20 pts | Both groups improved equally in cardiac function, no medical emergencies in either group | | II-B

Evidence Table 6. Studies of patient satisfaction for self-monitoring/testing

Source | Setting | Population | Study Design | | | | Results | Comments
| | | Type | Sample | Control | Instruments
Piette, 1997 ^ 81 ^ | Outpatient clinic patients | IDDM and NIDDM patients | III | Convenience sample | None | Satisfaction with automated voice messaging (AVM) system measured using system itself. Responses re: satisfaction on 82% of participants | Nearly all respondents felt AVM system was either very helpful or helpful. Most (77%) felt that AVM would make them more satisfied with their health care. Results varied somewhat with age | Program feasibility study
Edmonds, 1998 ^ 82 ^ | Patients using home blood glucose monitoring with telephone data uploading | Diabetic patients | II-B | Convenience sample of 35 patients | Randomized control | Validated questionnaire | Patients found the system easy to use and helpful in managing their glucose levels | Controls did not do questionnaires
Bai, 1996^ 83 ^ | University hospital and patients' homes | Patients with known cardiovascular disease and normal volunteers | III | Convenience sample 30 patients, 6 normal volunteers | None | Unknown | Both patients and volunteers rated the telemedicine service as necessary, convenient, and effective | Program evaluation no discussion of how satisfaction data were obtained
Finkelstein, 1998^ 142 ^ | Outpatient pulmonary clinic | Asthmatics | III | Convenience sample of 17 patients, 22-68 years of age | None | Unvalidated questionnaires | High degree of acceptance of home telemonitoring system; almost all expressed strong willingness to use such a system in the future.
Friedman, 1996^ 76 ^ | University hospital; patients' homes | HTN patients >60 yrs. Old | II-B | Convenience sample of 267 enrollees; randomly assigned 133 to treatment, 134 to control | Purposeful sample; randomized assignment | Personal interview using unvalidated structured questions given 6 months after treatment; use of visual analog scale | 69% were in upper quartile of visual analog scale (indicating satisfaction) for overall satisfactions and health benefit | Control group not questioned on satisfaction. No data on reliability or validity of satisfaction tools
Johnston, 2000^ 77 ^ | Staff-model HMO and patients' homes | Elderly patients with chronic disease | I-B | Convenience sample of 212 patients | Randomized control | Project-developed questionnaire | Patients found system was effective, timely, convenient, and provided appropriate care | Controls did not do questionnaires

Evidence Table 7. Studies of clinician-interactive services - dermatology

Source | Experiment | Gold Standard | Sample | Diagnosis | Management | Comments | Number of Clinicians | Study Class
Lesher, 1998^ 85 ^ | Diagnostic agreement of interactive video versus in-person exam | In-person exam | 60 pts with 115 problems | 78% agreement with telemed/local vs. 94% agreement with local/local | Not assessed | Compared telemedicine vs. in-person and in-person vs. in-person | 3 | II-C
Loane, 1998^ 86 ^ | Diagnostic and management plan agreement of interactive video versus in-person exam | In-person exam | 351 pts with 427 diagnoses | 67% of diagnoses in agreement | 64% had same management plan | 64% of pts seen by same dermatologist, with different results in diagnosis and management | Not stated | III-C
Oakley, 1997^ 87 ^ | Diagnostic agreement of interactive video versus in-person exam | In-person exam | 104 pts with 135 conditions | 75% of conditions correctly diagnosed | Not assessed | Most pts seen by same dermatologist (exact number not specified) | Not stated | III-C
Gilmour, 1998^ 88 ^ | Diagnostic agreement of interactive video versus in-person exam for skin tumors | In-person exam | 126 pts | 57% agreement on diagnosis | Not assessed | Half of pts seen by same dermatologist | 5 | III-C
Lowitt, 1998^ 89 ^ | Diagnostic agreement of interactive video versus in-person exam | In-person exam | 139 pts with 318 diagnoses | For paired observations, agreement 80%. For 11 pts with biopsies done, interpretation confirmed biopsy in 7, favored video diagnosis in 1, and revealed different diagnosis in 3 | Not assessed | Agreement only measured on observations made by both examiners | 4 | III-C
Phillips, 1998^ 90 ^ | Diagnostic and management plan agreement of interactive video versus in-person exam for skin tumors | In-person exam | 107 lesions in 51 pts | 59% agreement on diagnosis (kappa = 0.32) | 86% agreement on recommending biopsy (kappa = .47) | No actual biopsies so no gold standards | 2 | II-C

Evidence Table 8. Studies on clinician-interactive services - other clinical specialties

Source | Domain | Experiment | Gold Standard | Sample | Diagnosis | Management | Comments | Number of Clinicians | Study Class
Srikanthan, 1997^ 91 ^ | Cardiology | Fax of EKG to cardiologist by resident make diagnosis of MI and make decision to use thrombolytics | Cardiologist assessment | 112 pts | EKG misinterpretation 9% of time | Consultant agreed with decision to use thrombolytics 87.5% of time | | 13 | II-B
Trippi, 1996^ 92 ^ | Cardiology | Agreement of diagnostic dobutamine stress echo in ER for acute myocardial infarction | On-site interpretation of EKG | 26 pts | Agreement in 96% of pts but 88% of tests normal | Not assessed | Too many normals, protocol not exactly clear | 1 | III-C
Lee, 1998^ 93 ^ | ER | Effect of real-time teleradiology in changing diagnosis and treatment plans in ER | None | 123 studies with 460 films for 90 pts | Changed initial diagnosis in 30% of cases | Changed initial treatment plan in 26% of cases | | Not stated | II-B
Tachakra, 1996^ 94 ^ | ER | Accuracy of radiologic interpretation by nurse practitioners for "subtle" fractures | Interpretation by emergency physician | 60 x-ray studies | 95% of readings correct | Not assessed | Case selection arbitrary | 3 | III-B
Hubble, 1993^ 95 ^ | Neurology | Assessment of Parkinson's disease by interactive videoconferencing versus in-person | In-person exam | 9 pts | High correlation for subjective (0.97), objective (0.91), and staging (0.88) scores | Not assessed | | 2 | II-B
Marcus, 1998^ 57 ^ | Ophthalmology | Interactive video diagnosis of eye disease in HIV and diabetes mellitus | In-person exam | 34 eyes of 17 HIV pts, 39 eyes of 20 diabetes mellitus pts | For HIV retinopathy, sens = 83% and spec = 95%. For DM, unable to classify 46% of glaucoma and 36% of retinopathy due to cataract; poor sensitivity (29-50%) for those that could be assessed | Not assessed | | Not stated | II-C
Nitzkin, 1997^ 41 ^ | Ophthalmology and Physical Therapy | Interactive video ophthalmology and physical therapy exam findings by physicians and physical therapists | In-person exam | 58 pts with 1826 findings | Ophthalmology agreement 85.9% (kappa = 0.65), physician therapy agreement 87.7% (kappa = 0.61) | Not assessed | Users familiar with technology did better | 33 | III-B
Pacht, 1998^ 96 ^ | Pulmonary | History and physical examination via interactive videoconferencing by pulmonary specialists | In-person exam | 40 pts | Kappa for agreement varied from 0.29 (history) to 0.66 (physical exam) | Not assessed | | 4 | II-B
Baur, 1998^ 97 ^ | Dental | Agreement in orthognathic exam by interactive video and in-person exam | In-person exam | 13 pts | Percent agreement on exam classifications varied from 76.9% to 100% | Not assessed | Telemedicine and in-person exams done by same surgeon | 2 | III-B
Pedersen, 1994^ 98 ^ | ENT | General practitioners telementored using otorhinolaryngolic endoscopy (Phase 2) | Procedure performed by specialist | 17 pts | Agreement on diagnosis in all cases | Not assessed | | 2 | III-B
Montani, 1996^ 99 ^ | Psychology | Reliability of remote psychometric tests administered by interactive video to elderly pts | In-person exam | 9 pts | A small but statistically significant decrease in scores for remote pts | Not assessed | Elderly psych inpatients | 2 | II-C
Hayes, 1998^ 100 ^ | Urology | How often real and simulated teleconsults for urolithiasis change plan of care | None | 14 real and 18 simulated pts | | Telemedicine altered treatment recommendation in 50% of real and 17 of simulated pts | | 1 | III-C
Sclafani, 1999^ 53 ^ | ENT | Agreement of ENTs in remote non-interactive video versus store and forward exam | In-person exam | 45 pts | Diagnostic agreement 85% for local versus non-interactive and 64% for local versus store and forward | Not assessed | Real-time telemedicine examination was non-interactive | 5 | II-B

Evidence Table 9. Studies of access for clinician-interactive services

Source | Purpose | Design | | | Subjects | | Results | | Limitations
| | Study Class, Description | Intervention | Control | Population | Sample | More Care in Local Hospital | Access to Quicker Care
Bailes, 1997^ 101 ^ | Estimate savings of neurosurgery consults | III, case series, prospective | Consult via analog telephone line with PC image capture & receiving units & film digitizing for CT scan, MRI & cerebral angiography | Historic (no image transmittal & all consults at distant regional hospital) | Small-town pts with NS emergency or needing NS opinion | n = 100 consecutive telemedicine consults | n = spinal injury (33%), stroke (25%); intra-cranial hemorrhage (23%); tumor (21%); other (62%) did not require transfer with telemedicine | E = (n = 5 of 25, 20%) OR admits directly from helicopter | Criteria for remaining at primary hospital and reliability not reported
Goh, 1997^ 110 ^ | Evaluate impact of neurosurgery consults | II, non-random 2-group comparisons, prospective | Teleradiology for CT scan transmittal via analog telephone lines to NS PC or portable computer at the time of verbal referral | Pre-post | Small-town pts with NS emergency | E (post) = 66 pts referred by telemedicine, C (pre) = 50 pts referred by phone | 21% fewer transfers for any reason: E = 79% (52/66) C = 100% (50/50) Equal local access to urgent pre-transfer procedures E = 27% C = 20% (p = 0.41) | Equivalent transport time: E = 72 min C = 80 min (p = 0.38) | Unreported group assignment methods, significance of difference in transfer rates & times, reliability
Eljamel, 1992^ 103 ^ | Evaluate impact of NS consults | II, non-random 2-group comparison | CT scan transmittal & consult via analog telephone line | Historic (no CT scan transmittal) | Small-town pts with NS emergency transferred to larger hospital | E = 51 TMed users (pts) C = 52 non-users | Fewer unnecessary transfers (returns to home hospital within 24 hrs) E = 0 (0%) C = 17 (33%) | | Sample inclusion/exclusion criteria and reliability of triage decisions not reported
Brecht, 1996^ 104 ^ | Evaluate medical outcomes, economic impact & user satisfaction of telemedicine consults | III, case series, retrospective | Med-surg consults using cameras (room, pt, document & oto/opthalmoscope) & digital stethoscope image/data transmittal via T1 digital line, multi-unit conferencing, image annotation & audio recording during clinic visit | None | State prisoners N = 1,715 consecutive telemedicine consults | n = 576 consults n = 130 consults | Consultants estimated 95% of TMed consults saved 1+ trip Mean Transport Score 3.64 Scale to estimate required travel: (4) TMed x 1; (3) Travel + TMed; (2) TMed + TMed; (1) TMed + Travel; (0) TMed + Travel &/or TMed | | Sample selection methods & reliability not specified; results do not include frequencies; access may have been affected by unavailable equipment & MDs (e.g., ENT, Derm, Infectious Disease, Ophthalmology)
Navein, 1997^ 105 ^ | Evaluate effect of telemedicine for primary-care physicians on pt-evacuation rate | III, case series, retrospective | Video-teleconferencing | None | Consults for military personnel in peace-keeping operation | n = 53 consults | Per primary MD log & post-interview, evacuation changes: prevented 9, downgraded 2 from urgent to routine, implemented 2 that were not planned | | No comparison group, no relationships shown between subjects, decisions, outcomes
Shanit, 1996^ 106 ^ | Evaluate cardiology consults for primary care decisions, triage & workload prioritization | III, case series, prospective | Cardiac consults from office or pt's home, using analog lines, acoustic handheld ECG transmitter & voice access & computer receiver | None | Primary care physicians | n = 93 GPs in 26 health centers who made 2,563 consults | High GP ratings: Saved referrals 5 Quicker referrals 5 Scale: 6 (strongly agree) 1 (strongly disagree) | | Almost no data to validate assumptions about access improvements with cardiac consults for GPs
Srikanthan, 1997^ 91 ^ | Evaluate after-hrs consults for MI management | III, case series | ECG & clinical assessment faxed to consultant's home | None | Pts admitted after hrs to CCU with cardiac chest pain | n = 112 pts | n = 17 (15%) had more appropriate treatment after hours 100% had access to consultation not previously available | | Lack of independent decisions for comparison of primary provider & consultant, since consultant reviewed primary provider's decisions
Johnson, 1998^ 107 ^ | Compare on-site ultrasound with remote ultrasound | II, non-random 2-group comparison | Remote US scanning with digital store-and-forward image transmission, real-time video images & videoconferencing | On-site supervision of ultrasound studies with film review & direct second look scanning | Small-town family practice pts referred for non-urgent ultrasound | N = 146 sequential outpts E = 74 on days without on-site radiologist C = 72 on days with on-site radiologist | More local ultrasounds (transfer not required) E = 57% C = 21% | | Lack of randomization; missing data: E = 10 (14%), C = 28 (39%); significance of local care differences and reliability not reported

Evidence Table 10. Studies of health outcomes for clinician-interactive services

Source | Domain | Question | Control | Sample | Results | Comments | Class
Brennan, 1998^ 108 ^ | ER | Pts randomized to local or telemed care RCT | Local care | 100 pts | No difference in ER return or need for additional care | | I-A
Wootton, 2000^ 109 ^ | Dermatology | Need for special follow-up RCT | In-person care | 204 pts | No difference in need for follow-up | | II(b)-B
Goh, 1997^ 102 ^ | Neurosurgery | Neurosurgery transfer before and after teleradiology | Pts without teleradiology | 50 cases pre-teleradiology, 66 post | Fewer adverse events during transfer (8% vs. 32%) | | III-B
Goh, 1997^ 110 ^ | Neurosurgery | Head injury pts with teleradiology | Pts without teleradiology | 63 pts | Fewer adverse events during transfer (6.4% vs. 32.1%) | Subset of Goh, 1997^ 102 ^ | III-B
Moore, 1996^ 111 ^ | Urology | Remote telementoring of GU laparoscopic procedures by experienced surgeon | Side by side mentoring | 23 in exp, 12 in control | No increase in complications or time of operation | Case matching not described | III-B
Lambrecht, 1998^ 112 ^ | Orthopedics | Ortho outcomes | None | 91 consults | No adverse outcomes | No details given | III-C

Evidence Table 11. Studies of patient satisfaction for clinician-interactive services

Source | Setting | Population | Study Design | | | | Results | Comments
| | | Type | Sample | Control | Instruments
Brennan, 1998^ 108 ^ | Community hospital emergency departments | Emergency department patients | II-B | Convenience sample; randomized to telemedicine or no telemedicine | Randomly assigned | Follow up phone interview-unknown type | Patients were satisfied. No significant differences between telemedicine and control group on positive patient-physician, patient-nurse interaction, or overall satisfaction. | No information on types of questions, response rates for telephone follow-up, detail of data analysis
Allen, 1995^ 113 ^ | University hospital and remote sites | Cancer patients | III | Convenience sample of 39 patients who had teleconsults. 21 continued and were seen later in person | Same patients seen at a later date in person served as their own controls | Unvalidated questionnaires | Generally equally satisfied. Patients were more comfortable saying what they needed to say in person; after in-person visit, they were less inclined to want to use the videoconferencing system
Gilmour, 1998^ 88 ^ | Outpatient clinic patients | Dermatology | III | Convenience sample of 26 patients ranging in age from 3 months to 83 years | Patients served as their own controls | Unvalidated questionnaires | In general, patients indicated high levels of satisfaction with teleconsultation | Satisfaction questionnaires not administered after face-to-face consultation
Montani, 1996^ 99 ^ | Hospitalized elderly | Patients needing pychometric evaluation | III | Convenience sample of 15 hospitalized patients aged 83-95 years | Patients served as their own controls | Follow-up interviews; impressions of interviewer and independent observer | Most patients preferred face-to-face assessments; impressions of psychologists were similar | Data presented were difficult to interpret, especially the evaluations by the interviewer and independent observer ("psychologists").
Doze, 1999^ 116 ^ | Telepsychiatry. One center and 5 referral sites | Patient referred by GPs for psychiatric evaluation | III | Convenience sample some of the users (total number varied by question) | None | Non-validated questionnaires and telephone surveys | Overall, 84% of patients were satisfied. Less than half the respondents would rather use telepsychiatry in-person. | Part of program evaluation
Hubble, 1993^ 95 ^ | Outpatient medical clinic | Parkinson's disease patients | III | Convenience sample 9 patients | None | Exit interview; instrument not specified | 8 of 9 said they were not frightened by technology; 1 was "maybe" frightened
Callahan, 1998^ 143 ^ | Primary care physician's office | Patients referred by primary care physician for either mental health or non-mental health teleconsultation | II-b | Convenience sample 34 mental health patients 59 non-mental health patients | Non-mental health telemedicine encounters | Non-validated post visit evaluation forms | No significant differences noted between groups; mental health patients as satisfied as non-mental health patients. | No information on statistical tests used to determine significance; question use of non-mental health telemedicine patients as comparison group, vs. non-telemedicine mental health patients
Pedersen, 1995^ 144 ^ | General practitioner office | ENT patients | III | Convenience sample on randomly selected day | None | Unvalidated questionnaires | Overall, 18 of 24 patients were very satisfied; 5 satisfied, 1 dissatisfied | Questionnaires were given to 26 patients after visit, 24 were returned by mail. Not all respondents answered all questions.
McLaren, 1995^ 145 ^ | 2 adjacent psychiatric wards | Psychiatric in-patients | III | 105 interactions over 4 months | Not applicable | Interpreted observations, both real-time and video | A high level of patient acceptance was observed | Entirely qualitative study
Lowitt, 1998^ 89 ^ | VA clinic | Dermatology outpatients | III | Convenience sample 102 patients had both teleconsult and in person visit; 29 patients had in person visit only | None | Unvalidated questionnaires | "Patients were highly satisfied with teledermatology" | Satisfaction reported on teledermatology patients only
Rosengren, 1998^ 146 ^ | Emergency department | Eye patients | III | Convenience sample 24 patients seen; 20 patients surveyed | None | Retrospective telephone survey | All patients very satisfied. No one preferred transfer to larger facility. All would be happy to use telemedicine again. | Contents of telephone survey unknown
Loane, 1998^ 147 ^ | Outpatient clinic | Dermatology outpatients | III | Convenience sample. 334 patients seen; 292 completed satisfaction survey | None | Unvalidated questionnaires | Patients were satisfied. Per authors, results consistent with previous studies and indicate teledermatology was satisfactory to patients | Unvalidated questionnaires led to problems with data analysis; e.g., 16% of patients preferred teledermatology and traditional consultations
Huston, 1997^ 148 ^ | Telemedicine program | Multiple specialties and clinical nutrition | III | Convenience sample of 96 patients | None | Unvalidated questionnaires | Patients in rural eastern Kentucky were "very satisfied with telemedicine as a means of health care delivery." | Program evaluation
Reid, 1998^ 66 ^ | Outpatient clinic patients | Dermatology patients | III | 66 patients; unknown from report how they were chosen | None | Unvalidated questionnaires | Patients appeared very satisfied. All agreed that "This technology is of value to you and your community." | Program evaluation
Couturier, 1998^ 115 ^ | Geriatric rehab unit | Orthopedic patients | III | Convenience sample of 15 | None | Unvalidated questionnaires | Patient attitudes toward teleconsulting were favorable −9 rated as excellent; 3 as good; 3 unable to evaluate. Patients indicated a high level of satisfaction. | Program feasibility study
Clarke, 1997^ 118 ^ | Outpatient psychiatric clinic | Psychiatric patients | III | Convenience sample of 75 patients | None | Structured interviews by author; some patients also got questionnaires | 88% said they would use the service again; other results difficult to interpret | Numerous methodological difficulties with this paper. The primary purpose of the study was to describe the patient population that used the telepsychiatry service.
Harrison, 1996^ 149 ^ | GP's offices | A variety of hospital based specialists | III | Convenience sample of 54 patients | None | Unvalidated, self-administered questionnaires | Patients were generally satisfied with the experience of television link and would use it again. | Minimal analysis and discussion of results

Evidence Table 12. Studies of physician/provider satisfaction for clinician-interactive services

Source | Setting | Population | Study Design | | | | | Results | Comments
| | | Study class | Sample | Site(s) | Control | Instruments
Couturier, 1998^ 115 ^ | Geriatric rehab unit | Orthopedist and referring doctor | III | Convenience sample of 1 orthopedist; 1 referring doctor | 1 | None | Unclear from study whether this was by questionnaire or interview | Telemedicine consultation was satisfactory in terms of quality of image, sound, clinical exam and simplicity. Teleconsultation was perceived as being significantly longer by the orthopedist; otherwise the two doctors were equally satisfied. | Program feasibility study
Gilmour, 1998^ 88 ^ | Outpatient dermatology clinic | 5 dermatologists; 27 GPs | III | Convenience sample | 3 | None | Unvalidated questionnaires | GPs overwhelmingly reported teleconsultation valuable | Satisfaction results reported for only 1 of 3 sites; no supporting data provided
Doze, 1999^ 116 ^ | Telepsychiatry; 1 center, 5 referral sites | Service providers and consulting psychiatrists | III | Convenience sample, no information on sample sizes | 1 | None | Unvalidated questionnaire | Physicians who used telepsychiatry expressed satisfaction with the service | No data provided to support results
Reid, 1998^ 66 ^ | Teleradiology & teledermatology | Radiologists & dermatologists | III | Unknown number of referring physicians; 1 dermatologist; 1 radiologist | Dermatology referral sites (3); radiology referral sites (2); central site (1) | None | Unknown for dermatology; focus group discussion for radiology | Referring physicians and teleconsultants in both groups were very satisfied with technology and convenience | Contents of provider interviews not available; no data presented
Ricci, 1998^ 117 ^ | Surgical offices | Vascular surgeons | III | Convenience sample, n = 30 | Unknown | None | Unvalidated questionnaire | Technical quality satisfactory or better (97%); audio (97%); overall visit as good or better than in-person visit (97%)
Clarke, 1997^ 118 ^ | Outpatient psychiatry | General practitioner, nursing, other referrers for each patient | III | Convenience sample (number not specified) | 1 | None | Unvalidated questionnaire | High satisfaction ratings, no statistical significance | Study was done primarily to describe the patient population assessed by the telepsychiatry service
Lowitt, 1998^ 89 ^ | VA clinic | Dermatologists | III | n = 4 dermatologists | 1 | None | Unvalidated questionnaire | Physicians were highly satisfied with interpersonal aspects of both in-person and video visits; no significant differences in satisfaction among the 4 dermatologists | No information about questionnaire or data analysis
Rosengren, 1998^ 146 ^ | Emergency department | Emergency room physicians; consultant ophthalmologists | III | 6 medical officers; 3 specialists | 1 | None | Structured interviews | All medical officers felt comfortable with technology; all felt the consult assisted them in patient management; consultants felt comfortable with the concept, were satisfied with quality of exam, felt quality could be improved | Contents of provider interviews not available; no data presented
Whitten, 1998^ 150 ^ | Home health | Home health nurses | III | Convenience sample, n = 6 nurses | 1 | None | Interview in person or by phone | Overwhelmingly felt system was effective; cited disadvantages as well as advantages | Data only partially supports results