# Bibliography

$520 million spent on telemedicine worldwide in 1996 Most sales in Europe, North America, Pacific Rim Telemedicine & Virtual Reality 1997 2(8):85 6
AARP. Understanding senior housing for the 1990s. Washington, DC: American Association of Retired Persons; 1990.
Abastado M, Vilotijevic B, Abastado P Transtelephonic ECG monitoring. Report of a case of ventricular tachycardia Urgences Medicales 1997 16(4):179 81
Abdel-Malek A Telemammography feasibility Telemedicine Today 1996 4(6):36 7 10165149
Abel EA Treatment settings Clinics in Dermatology 1997 15(5):823 30 9313979
Ablaza VJ, Fisher J Wound care via telemedicine: the wave of the future Home Healthcare Consultant 1998 5(8):12 6
Adachi H, Inoue J, Nozu T, et al Frozen-section services by telepathology: experience of 100 cases in the San-in District, Japan Pathology International 1996 46(6):436 41 8869995
Adams LN, Grigsby RK The Georgia State Telemedicine Program: initiation, design, and plans Telemedicine Journal 1995 1(3):227 35 10165159
HCPCS code listings.
Ahring KK, Ahring JP, Joyce C, et al Telephone modem access improves diabetes control in those with insulin-requiring diabetes Diabetes Care 1992 15(8):971 75 1505329
Air Force Base saves money using telemedicine Telemedicine & Virtual Reality 1998 3(7).
Albisser AM, Harris RI, Sakkal S, et al Diabetes intervention in the information age Medical Informatics 1996 21(4):297 316 9179834
Alemi F, Stephens RC, Javalghi RG, et al A randomized trial of a telecommunications network for pregnant women who use cocaine Medical Care 1996 34(10 Suppl):OS10 20 8843933
Alemi F, Stephens R Computer services to patients' homes through their telephones. Application to other disease management efforts Medical Care 1996 34(10 Suppl):OS52 5 8843937
Alemi F, Stephens RC, Muise K, et al Educating patients at home. Community Health Rap Medical Care 1996 34(10 Suppl):OS21 31 8843934
Alexander M Telemedicine in Australia. 2: the Health Communication Network Journal of Telemedicine & Telecare 1996 2(1):1 6 9375035
Allen A, Hayes J Patient satisfaction with teleoncology: a pilot study Telemedicine Journal 1995 1(1):41 6 10165321
Allen A, Scarbrough ML 3rd annual program review Telemedicine Today 1996 4(4):10 7 10165139
Allen A, Roman L, Cox R, et al Home health visits using a cable television network: user satisfaction Journal of Telemedicine & Telecare 1996 2(Suppl 1):92 4 9375106
Allen A, Grigsby B 5th annual program survey-Part 2. Consultation activity in 35 specialties Telemedicine Today 1998 6(5):18 9 10339332
Allen A Prison telemedicine to Stringtown Telemedicine Today 1998 6(3):40 1 10183146
Almazan C, Gallo P. Assesssing clinical benefit and economic evaluation in telemedicine. Barcelona: Catalan Agency for Health Technology Assessment; 1999 May, 1999.
Amenta F, Dauri A, Rizzo N Organization and activities of the International Radio Medical Centre (CIRM) Journal of Telemedicine & Telecare 1996 2(3):125 31 9375045
Angood PB, Doarn CR, Holaday L, et al The Spacebridge to Russia Project: Internet-based telemedicine Telemedicine Journal 1998 4(4):305 11 10220470
Annual report to Congress 1995. Washington, DC 1995;466.
Anogianakis G, Maglavera S. MERMAID 1996-report on the implementation of a European Project on "medical emergency aid through telematics". Studies in Health Technology & Informatics. 1997;39:264-70. [pmid: 10168920].
Anogianakis G, Maglavera S. Transeuropean network for the provision of added-Value Services in Telemedicine-(VAST-Net). Studies in Health Technology & Informatics. 1997;39:298-306. [pmid: 10168925].
Anogianakis G, Maglavera S, Pomportsis A, et al Medical emergency aid through telematics: design, implementation guidelines and analysis of user requirements for the MERMAID project Int J Med Inform 1998 52(1-3):93 103 9848406
Anonymous. Telemedicine: A Guide to Assessing Telecommunications in Health Care. Washington, DC: National Academy Press; 1996.
Anonymous Diabetes-related amputations of lower extremities in the Medicare population-Minnesota, 1993-1995 MMWR - Morbidity & Mortality Weekly Report 1998 47(31):649 52 9716396
Antman EM, Ludmer PL, McGowan N, et al Transtelephonic electrocardiographic transmission for management of cardiac arrhythmias American Journal of Cardiology 1986 58(10):1021 4 3776841
Appalachia telemedicine projects show cost savings Telemedicine & Virtual Reality 1997 2(9).
Appleby C Telemedicine Oklahoma's highway to health. Hospitals & Health Networks 1997 71(6):
Armstrong I, Haston W The SAVIOUR project: a review Journal of Telemedicine & Telecare 1996 2(Suppl 1):84 6 9375103
Armstrong IJ, Haston WS Medical decision support for remote general practitioners using telemedicine Journal of Telemedicine & Telecare 1997 3(1):27 34 9139758
American Medical Association. Current Procedural Terminology.
Aucar JA, Doarn CR, Sargsyan A, et al Use of the Internet for long-term clinical follow-up Telemedicine Journal 1998 4(4):371 4 10220478
Baer L, Elford DR, Cukor P Telepsychiatry at forty: what have we learned? Harvard Review of Psychiatry 1997 5(1):7 17 9385015
Bai J, Zhang Y, Dai B, et al The design and preliminary evaluation of a home electrocardiography and blood pressure monitoring network Journal of Telemedicine & Telecare 1996 2(2):100 6 9375070
Bailes JE, Poole CC, Hutchison W, et al Utilization and cost savings of a wide-area computer network for neurosurgical consultation Telemedicine Journal 1997 3(2):135 9 10168279
Bailes JE, Poole CC, Manni PJ NeuroLink. Implementation of a wide-area neurosurgical consultation service Telemedicine Today 1997 5(3):26 9 10169674
Balas EA, Jaffrey F, Kuperman GJ, et al Electronic communication with patients evaluation of distance medicine technology Jama 1997 278(2):152 9 9214532
Balch DC, Tichenor JM Telemedicine expanding the scope of health care information Journal of the American Medical Informatics Association 1997 4(1):1 5 61191 8988467
Ball C, Puffett A The assessment of cognitive function in the elderly using videoconferencing Journal of Telemedicine & Telecare 1998 4(Suppl 1):36 8 9640728
Ballard JE, Liu J, Uberuagua D, et al Assessing influenza immunization rates in Medicare managed care plans: a comparison of three methods Joint Commission Journal on Quality Improvement 1997 23(8):434 42 9330084
Banach L Telemedicine in Transkei, South Africa Electron J Pathol Histol 1998 4(4):1 5
Bankhead C Innovations. Tele-oncology clinic helps rural cancer patients Radiation Therapist: the Journal of the Radiation Oncology Sciences 1997 6(2):159 60
Bartunek P, Gorican K, Zapletalova J, et al Transmission of the electrocardiogram via telephone. Analysis of 10 years' experience Casopis Lekaru Ceskych 1996 135(12):385 8 8706077
Basset JA, Tapuska B, Ford P, et al Enteral nutrition: hospital to home a collaborative approach to education and care Perspectives 1997 21(3):2 6 9355599
Baur DA, Pusateri AE, Kudryk VL, et al Accuracy of orthognathic evaluation using telemedicine technology Telemedicine J 1998 4(2):153 60
Bazex J, Barrie L, Civatte J Teledermatology-importance of telemedicine and dermatology Bulletin de l'Academie Nationale de Medecin 1999 183(2):357 67 discussion 68-70
Beard DV, Hemminger BM, Keefe B, et al Real-time radiologist review of remote ultrasound using low-cost video and voice Investigative Radiology 1993 28(8):732 4 8376006
Beck RD, Saddler C, Ranch R Preliminary experience with an orthopedic teleradiology service at the Alaska Native Medical Center International Journal of Circumpolar Health 1998 57(Suppl 1):689 90 10093369
Becker RL, Jr., Specht CS, Jones R, et al Use of remote video microscopy (telepathology) as an adjunct to neurosurgical frozen section consultation Human Pathology 1993 24(8):909 11 8375860
Belas EA, Jaffrey F, Pinciroli F. Patient care from a distance: analysis of evidence [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 12.
Bellazzi R, Siviero C, Stefanelli M, et al Adaptive controllers for intelligent monitoring Artificial Intelligence in Medicine 1995 7(6):515 40 8963374
Belmont JM, Mattioli LF, Goertz KK, et al Evaluation of remote stethoscopy for pediatric telecardiology Telemedicine Journal 1995 1(2):133 49 10165332
Bergman R Computers make 'house calls' to patients Hospitals 1993 67(10):
Bergmo TS An economic analysis of teleradiology versus a visiting radiologist service Journal of Telemedicine & Telecare 1996 2(3):136 42 9375047
Bergmo TS An economic analysis of teleconsultation in otorhinolaryngology Journal of Telemedicine & Telecare 1997 3(4):194 9 9614733
Berry RF, Barry MH Evaluation of a personal-computer-based teleradiology system serving an isolated Canadian community Canadian Association of Radiologists Journal 1998 49(1):7 11 9494458
Bertazzoni G, Genuini I, Aguglia F Telecar: an Italian telecardiology project Journal of Telemedicine & Telecare 1996 2(3):132 5 9375046
Bieze J Tech assessment adapts to image communication Diagnostic Imaging 1995 17(9):71 5 10155623
Bilalovic N, Paties C, Mason A Benefits of using telemedicine and first results in Bosnia and Herzegovina Journal of Telemedicine & Telecare 1998 4(Suppl 1):91 3 9640751
Billiard A, Rohmer V, Roques M, et al Telematic transmission of computerized blood glucose profiles for IDDM patients Diabetes Care 1991 14(2):130 34 2060415
Blackmon LA, Kaak HO, Ranseen J Consumer satisfaction with telemedicine child psychiatry consultation in rural Kentucky Psychiatric Services 1464 48(11):1464 6 9355177
Blackwell NA, Kelly GJ, Lenton LM Telemedicine ophthalmology consultation in remote Queensland Medical Journal of Australia 1997 167(11-12):583 6 9418795
Blue Cross of California gets $1.8 million for rural telemedicine program Telemedicine & Virtual Reality 1998 3(12).
Boeryd BR Experience with distant pathology demonstrations for clinicians in hospitals without local pathologists through the Swedish telepathology work station Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):266 7 8526565
Bolte R, Lehmann KJ, Walz M, et al Radiologic medical desktop conferences-clinical evaluation of the KAMEDIN teleradiology system in routine practice of a radiologic institute Aktuelle Radiologie 1996 6(4):199 202 8924455
Brecht RM, Gray CL, Peterson C, et al The University of Texas Medical Branch-Texas Department of Criminal Justice Telemedicine Project: findings from the first year of operation Telemedicine Journal 1996 2(1):25 35 10165347
Brennan JA, Kealy JA, Gerardi LH, et al A randomized controlled trial of telemedicine in an emergency department Journal of Telemedicine & Telecare 1998 4(Suppl 1):18 20 9640721
Brown FW Rural telepsychiatry Psychiatric Services 1998 49(7):963 4 9661235
Bruderman I, Abboud S Telespirometry: novel system for home monitoring of asthmatic patients Telemedicine Journal 1997 3(2):127 33 10168278
Brunicardi BO Financial analysis of savings from telemedicine in Ohio's prison system Telemedicine J 1998 4(1):49 54
Burdick AE, Berman B. Teledermatology. Advances in Dermatology. 1997;12:19-45. discussion 6. [pmid: 8973734].
Burgiss SG, Julius CE, Watson HW, et al Telemedicine for dermatology care in rural patients Telemedicine Journal 1997 3(3):227 33 10174347
Burns RB, Crislip D, Daviou P, et al Using telerehabilitation to support assistive technology Assistive Technology 1998 10(2):126 33 10339280
Busack G Rural connections. Iowa hospitals are establishing communications link to better serve rural areas Health Progress 1994 75(3):48 50 10132878
Busch C Telepathology in Sweden. A national study including all histopathology and cytology laboratories Zentralblatt fur Pathologie 1992 138(6):429 30 1297437
Butler RN, Sherman FT, Rhinehart E, et al Managed care: What to expect as Medicare-HMO enrollment grows Geriatrics 1996 51(10):35 42
Butler RN, Sherman FT, Rhinehart E, et al Managed care: what to expect as Medicare-HMO enrollment grows. 1 Geriatrics 1996 51(10):35 42
Calcagni DE, Clyburn CA, Tomkins G, et al Operation Joint Endeavor in Bosnia: telemedicine systems and case reports Telemedicine Journal 1996 2(3):211 24 10165544
Caldwell MA, Miles R, Barrington W. Long distance transmission of diagnostic cardiovascular information. Biomedical Sciences Instrumentation. 1996;32:1-6. [pmid: 8672654].
Callahan EJ, Hilty DM, Nesbitt TS Patient satisfaction with telemedicine consultation in primary care: comparison of ratings of medical and mental health applications Telemedicine J 1998 4(4):363 9
Callas PW, McGowan JJ, Leslie KO Provider attitudes toward a rural telepathology program Telemedicine Journal 1996 2(4):319 29 10165369
Cameron AE, Bashshur RL, Halbritter K, et al Simulation methodology for estimating financial effects of telemedicine in West Virginia Telemedicine J 1998 4(2):125 41
Campbell NC, Ritchie LD, Cassidy J, et al Systematic review of cancer treatment programmes in remote and rural areas British Journal of Cancer 1999 80(8):1275 80 10376984
Capuano TA, Molchany C, Potylycki MJ, et al Remote monitoring. Expanding a successful system Nursing Management 1997 28(5):
Carrasquillo O, Himmelstein DU, Woolhandler S, et al Going bare: trends in health insurance coverage, 1989 through 1996 [published erratum appears in Am J Public Health 1999 Feb;89(2):256] American Journal of Public Health 1999 89(1):36 42 9987462 1508508
Cartwright W Objective measurement of anxiety in hypertensive pregnant women managed in hospital and in the community British Journal of Obstettics and Gynaecology 1992 99(March):182 5
Case study: interactive video communications in health care. In: Proceedings of the. 1996;1996:133-40.
Casey F, Brown D, Craig BG, et al Diagnosis of neonatal congenital heart defects by remote consultation using a low-cost telemedicine link Journal of Telemedicine & Telecare 1996 2(3):165 9 9375052
Casey F, Brown D, Corrigan N, et al Value of a low-cost telemedicine link in the remote echocardiographic diagnosis of congenital heart defects Journal of Telemedicine & Telecare 1998 4(Suppl 1):46 8 9640733
Charles R Drew University cited for inner-city telemedicine Telemedicine & Virtual Reality 1998 3(9).
Chesnut R, Carney N, Maynard H, et al. Rehabilitation for Traumatic Brain Injury. Evidence report no. 2 (Contract 290-97-0018 to Oregon Health Sciences University). Rockville, MD: Agency for Health Care Policy and Research; 1999 1999.
Cheung ST, Davies RF, Smith K, et al The Ottawa telehealth project Telemedicine J 1998 4(3):259 66
Choi J, Kim Y, Lee S, et al Features for a B-ISDN telemedicine system and its application Medinfo 1998 9(Pt 1):307 10 10384468
Chriss L Specialty snapshot. Video calls connect home care nurses with patients Nurseweek 1996 9(6):
Clark G On-line midwives... using telemedicine Nursing Times 1996 92(3):18 9 8577597
Clarke PH A referrer and patient evaluation of a telepsychiatry consultation-liaison service in South Australia Journal of Telemedicine & Telecare 1997 3(Suppl 1):12 4 9218368
Coleman AL, Morgenstern H Use of insurance claims databases to evaluate the outcomes of ophthalmic surgery Survey of Ophthalmology 1997 42(3):271 8 9406373
Commission PPR. Annual Report to Congress Chapter 7: Telemedicine Services.
Report prepared by the Physician Payment Review Commission. 1995.
Conklin G Voice/video/data telemedicine at INTEGRIS Health: how it fits into the overall telecommunications system Health Management Technology 1998 19(1):32 3 10177934
Conrath DW, Dunn EV, Bloor WG, et al A clinical evaluation of four alternative telemedicine systems Behavioral Science 1977 22(1):12 21 405004
Cook JF, Hansen MF, Leckie RG, et al AKAMAI Project: teleradiology in the Pacific Journal of Digital Imaging 1995 8(1 Suppl 1):
Cook CB, Penman A, Cobb AB, et al Outpatient diabetes management of Medicare beneficiaries in four Mississippi fee-for-service primary care clinics Journal of the Mississippi State Medical Association 1999 40(1):8 13 9919044
Cook JF, Rozenblit JW, Chacko AK, et al Meta-manager: a requirements analysis Journal of Digital Imaging 1999 12(2 Suppl 1):186 8 10342206
Cooper GS, Yuan Z, Stange KC, et al The utility of Medicare claims data for measuring cancer stage Medical Care 1999 37(7):706 11 10424641
Coppola MP, Lawee M Management of obstructive sleep apnea syndrome in the home. The role of portable sleep apnea recording Chest 1993 104(1):19 25 8325068
Corr P Teleradiology in KwaZulu-Natal. A pilot project South African Medical Journal 1998 88(1):48 9 9539937
Couturier P, Tyrrell J, Tonetti J, et al Feasibility of orthopaedic teleconsulting in a geriatric rehabilitation service Journal of Telemedicine & Telecare 1998 4(Suppl 1):85 7 9640749
Cox R, York ML Rural telemedicine - the electronic signal flows in both directions Best Practices & Benchmarking in Healthcare: a Practical Journal for Clinical & Management Applications 1997 2(1):28 32
Coyle G, Boydell L, Brown L Home telecare for the elderly Journal of Telemedicine & Telecare 1995 1(3):183 4 9375140
Crawford D Georgia Medical Center delivers home health care Telemedicine & Virtual Reality 1997 2(11).
Crist TM, Kaufman SB, Crampton KR Home telemedicine: a home health care agency strategy for maximizing resources Home Health Care Management & Practice 1996 8(4):1 9
Cross M Telemedicine. Choosing the right technology Health Data Management 1996 4(6):75 7 10158055
Crowe BL, Hailey DM, de Silva M. Evaluation of teleradiology at a children's hospital [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care.
Crowe BL, Hailey DM, Carter R Assessment of costs and benefits in the introduction of digital radiology systems International Journal of Bio-Medical Computing 1992 30(1):17 25 1551733
Crowe BL, Hailey DM, de Silva M Teleradiology at a children's hospital: a pilot study Journal of Telemedicine & Telecare 1996 2(4):210 6 9375061
Crowe B Establishing the costs of telemedicine services Minimally Invasive Therapy 1997 6(5-6):432 5
Crowe BL, McDonald IG Telemedicine in Australia. Recent developments Journal of Telemedicine & Telecare 1997 3(4):188 93 9614732
Crump WJ, Tessen RJ Communication in integrated practice networks: using interactive video technology to build the medical office without walls Texas Medicine 1997 93(3):70 5 9062464
Cubano M, Poulose BK, Talamini MA, et al Long distance telementoring. A novel tool for laparoscopy aboard the USS Abraham Lincoln Surgical Endoscopy 1999 13(7):673 8 10384073
Currell R, Urquhart C, Wainwright P, et al. Telemedicine versus face-to-face consultations: effects on professional practice and health care outcomes. Oxford; 2000.
Curtis DJ, Gayler BW, Gitlin JN, et al Teleradiology: results of a field trial Radiology 1983 149(2):415 8 6622684
Dakins DR Rural network extends reach of teleradiology Diagnostic Imaging 1995 17(11):103 6 10163589
Dakins DR, Jones E Cream of the crop: 10 outstanding telemedicine programs Telemedicine & Telehealth Networks 1996 2(11):24 34 10165835
Dakins DR Nebraska network passes milestone with 509 patient encounters Telemedicine & Telehealth Networks 1997 3(2):11 2 10166433
Dalhousie medical school exports telemedicine services Telemedicine & Virtual Reality 1998 3(7):
Dannenfeldt D Building an electronic highway for rural America Health Data Management 1995 3(3):25 7 10143580
Danneskjold-Samsoe B, Arnlind M, Palsson T, et al. Telemedicine in the Nordic countries - attitudes and diffusion [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 4.
Dansky K, Dirani R The use of health care services by people with diabetes in rural areas Journal of Rural Health 1998(14):129 37
Dansky KH, Dirani R The use of health care services by people with diabetes in rural areas Journal of Rural Health 1998 14(2):129 37 9715001
Dansky KH, Brannon D, Shea DG, et al Profiles of hospital, physician, and home health service use by older persons in rural areas Gerontologist 1998 38(3):320 30 9640852
Darkins A, Dearden CH, Rocke LG, et al An evaluation of telemedical support for a minor treatment centre Journal of Telemedicine & Telecare 1996 2(2):93 9 9375069
Darkins A, Fisk N, Garner P, et al Point-to-point telemedicine using the ISDN Journal of Telemedicine & Telecare 1996 2(Suppl 1):82 3 9375102
Daus C Long-distance healing... telemedicine links outlying patients with asthma clinics and pulmonologists Rt: the Journal for Respiratory Care Practitioners 1997 10(2):73 5
Davis MC Teleradiology in rural imaging centres Journal of Telemedicine & Telecare 1997 3(3):146 53 9489109
Davis MC MR teleradiology network serving remote imaging centers Journal of Digital Imaging 1998 11(3 Suppl 1):88 92 9735441
Davis M, Poisal J, Chulis G, et al Prescription drug coverage, utilization, and spending among Medicare beneficiaries Health Affairs 1999 18(1):231 43 9926660
Dawood ME Developing telemedical facilities for emergency nurse practitioners in nurse-led minor accident treatment services Accident & Emergency Nursing 1998 6(4):207 10 10232099
De Sutter E, Duveau P, Hache JC. Remote diagnosis in ophthalmology. Bulletin de la Societe Belge d Ophtalmologie. 1994;254:67-70. [pmid: 7493127].
De Sutter E, De Molder R, Gabriel P, et al. Tele-Ophthalmology. The T. I. M. E. project. A Tele-Medicine project in the region Nord-Pas de Calais and Zuid-West-Vlaanderen. Bulletin de la Societe Belge d Ophtalmologie. 1994;252:37-42. [pmid: 7894754].
DeCorato DR, Kagetsu NJ, Ablow RC Off-hours interpretation of radiologic images of patients admitted to the emergency department: efficacy of teleradiology American Journal of Roentgenology 1995 165(5):1293 6 7572522
Defense Department gets its telemedicine Mobile Breast Care Center ready to travel Telemedicine & Virtual Reality 1997 2(11).
Delaplain CB, Lindborg CE, Norton SA, et al Tripler pioneers telemedicine across the Pacific Hawaii Medical Journal 1993 52(12):338 9 8125776
Della Mea V, Forti S, Puglisi F, et al Telepathology using Internet multimedia electronic mail: remote consultation on gastrointestinal pathology Journal of Telemedicine & Telecare 1996 2(1):28 34 9375039
Della Mea V, Beltrami CA Telepathology applications of the Internet multimedia electronic mail Medical Informatics 1998 23(3):237 44 9785326
di Biase N, Napoli A, Sabbatini A, et al Telemedicine in the treatment of diabetic pregnancy Annali dell Istituto Superiore di Sanita 1997 33(3):347 51 9542261
Dick PT, Filler R, Pavan A Participant satisfaction and comfort with multidisciplinary pediatric telemedicine consultations Journal of Pediatric Surgery 1999 34(1):137 41 discussion 41-2 10022159
Directory FT. Federal Telemedicine Directory 1998. 1998.
Doolittle G A POTS-based tele-hospice project in Missouri Telemedicine Today 1997 5(4):18 9 10174244
Doolittle GC, Harmon A, Williams A, et al A cost analysis of a tele-oncology practice Journal of Telemedicine & Telecare 1997 3(Suppl 1):20 2 9218371
Doolittle GC, Williams A, Harmon A, et al A cost measurement study for a tele-oncology practice Journal of Telemedicine & Telecare 1998 4(2):84 8 9744163
Doolittle GC, Yaezel A, Otto F, et al Hospice care using home-based telemedicine systems Journal of Telemedicine & Telecare 1998 4(Suppl 1):58 9 9640738
159 Doty E, Zincone LH, Jr., Balch DC. Telemedicine in the North Carolina prison system. A cost-benefits analysis. Studies in Health Technology & Informatics. 1996;29:239-41. [pmid: 10163755].
Doz S, Simpson J Report from the Alberta Heritage Foundation for Medical Research. Evaluation of a telepsychiatry pilot project International Journal of Technology Assessment in Health Care 1998 14(3):583 4 9780544
Doze S, Simpson J, Hailey D, et al Evaluation of a telepsychiatry pilot project Journal of Telemedicine & Telecare 1999 5(1):38 46 10505368
Drummond MF Allocating resources International Journal of Technology Assessment in Health Care 1990 6(1):77 92 2113892
Drummond M, Richardson W, O'Brien B, et al. User's guide to the medical literature. XIII. How to use an article on economic analysis of clinical practice. A. Are the results of the study valid?. JAMA. 1997;277:1552-7. [pmid: 9153371].
Drummond M, O'Brien B, Stoddart G, et al. Methods for the Economic Evaluation of Health Care Programmes. Second Edition ed. Oxford: Oxford University Press; 1997.
Duffy JR, Werven GW, Aronson AE Telemedicine and the diagnosis of speech and language disorders Mayo Clinic Proceedings 1116 72(12):1116 22 9413290
Dunbar C University of Iowa links rural providers Health Management Technology 1994 15(9):20 2 10136887
Edmonds M, Bauer M, Osborn S, et al Using the Vista 350 telephone to communicate the results of home monitoring of diabetes mellitus to a central database and to provide feedback International Journal of Medical Informatics 1998 51(2-3):117 25 9794328
Egglin TK, Feinstein AR Context bias. A problem in diagnostic radiology Jama 1996 276(21):1752 5 8940325
Eide TJ, Nordrum I Frozen section service via the telenetwork in northern Norway Zentralblatt fur Pathologie 1992 138(6):409 12 1297433
Eide TJ, Nordrum I Current status of telepathology Apmis 1994 102(12):881 90 7888156
Eilertsen TB, Kramer AM, Schlenker RE, et al Application of functional independence measure-function related groups and resource utilization groups-version III systems across post acute settings Medical Care 1998 36(5):695 705 9596060
Elford R, White H, Bowering R, et al. Child Telepsychiatry: A randomized, controlled trial of child psychiatric assessments conducted using a videoconferencing system. J Telemed Telecare 2000;6(2):73-82.
Elford DR Telemedicine in northern Norway Journal of Telemedicine & Telecare 1997 3(1):1 22 9139756
Elford R Telemedicine activities at Memorial University of Newfoundland: a historical review, 1975-1997 Telemedicine J 1998 4(3):207 24
Elford R. The Child telepsychiatry project. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999 June 6-10; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 11.
Eljamel MS, Nixon T The use of a computer-based image link system to assist inter-hospital referrals British Journal of Neurosurgery 1992 6(6):559 62 1472322
Engelmann U, Schroter A, Baur U, et al Experiences with the German teleradiology system MEDICUS Computer Methods & Programs in Biomedicine 1997 54(1-2):131 9 9290928
Engelmann U, Schroter A, Baur U, et al The German teleradiology system MEDICUS: system description and experiences in a German field test European Journal of Radiology 1998 26(3):219 25 9587745
Erlanger Health System introduces real-time cardiac telemedicine Telemedicine & Virtual Reality 1998 3(5):
Ermer DJ Experience with a rural telepsychiatry clinic for children and adolescents Psychiatric Services 1999 50(2):260 1 10030487
Ernst C Transtelephonic cardiac monitoring Journal of Health Care Benefits 1994 4(2):57 60 10154529
Falconer J, Giles W, Villanueva H Realtime ultrasound diagnosis over a wide-area network (WAN) using off-the-shelf components Journal of Telemedicine & Telecare 1997 3(Suppl 1):28 30 9218374
Fallucca F, Di Biase N, Sabbatini A, et al Telemedicine in the treatment of diabetic pregnancy Practical Diabetes International 1996 13(4):115 8
Falsone JJ, Moidu K, Sheehan CA, et al Is telemedicine justifiable? Connecticut Medicine 1998 62(7):423 7 9707797
Ferguson EW, Doarn CR, Scott JC Survey of global telemedicine Journal of Medical Systems 1995 19(1):35 46 7790806
Ferguson B, Keen J Transaction costs, externalities and information technology in health care Health Economics 1996 5(1):25 36 8653190
Ferrer-Roca O, Diaz-Cardama A, Pitti S, et al Telemedicine in the Canary Islands Lancet 1995 345(8958):1177 8 7723566
Ferrucci L, Guralnik JM, Pahor M, et al Hospital diagnoses, Medicare charges, and nursing home admissions in the year when older persons become severely disabled Journal American Medical Association 1997 277(9):728 34
Ferrucci L, Guralnik JM, Pahor M, et al Hospital diagnoses, Medicare charges, and nursing home admissions in the year when older persons become severely disabled Jama 1997 277(9):728 34 9042845
Ferry J Virtual doctors on the horizon in Seattle Lancet 1999 354(9182):
Fery-Lemonnier E, David P, Marsault C, et al. Impact of inter-hospital transmission of radiological images in the context of neurosurgical emergencies [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care.
Finkelstein SM, Lindgren B, Prasad B, et al Reliability and validity of spirometry measurements in a paperless home monitoring diary program for lung transplantation Heart & Lung 1993 22(6):523 33 8288456
Finkelstein J, Hripcsak G, Cabrera MR. Patients' acceptance of Internet-based home asthma telemonitoring. Proceedings/AMIA Annual Symposium. 1998:336-40.
Finkelstein J, Hripcsak G, Cabrera M Telematic system for monitoring of asthma severity in patients' homes Medinfo 1998 9(Pt 1):272 6 10384460
Finley JP, Sharratt GP, Nanton MA, et al Paediatric echocardiography by telemedicine-nine years' experience Journal of Telemedicine & Telecare 1997 3(4):200 4 9614734
Fisk NM, Sepulveda W, Drysdale K, et al Fetal telemedicine: six month pilot of real-time ultrasound and video consultation between the Isle of Wight and London British Journal of Obstetrics & Gynaecology 1996 103(11):1092 5 8916994
Flaker GC, McGowan DJ, Boechler M, et al Underutilization of antithrombotic therapy in elderly rural patients with atrial fibrillation American Heart Journal 1999 137(2):307 12 9924165
Flanigan MJ, Bailie GR, Frankenfield DL, et al 1996 Peritoneal Dialysis Core Indicators Study: report on nutritional indicators Peritoneal Dialysis International 1998 18(5):489 96 9848627
Flatley-Brennan P Computer network home care demonstration: a randomized trial in persons living with AIDS Computers in Biology & Medicine 1998 28(5):489 508 9861507
Fleming ST, Rastogi A, Dmitrienko A, et al A comprehensive prognostic index to predict survival based on multiple comorbidities: a focus on breast cancer Medical Care 1999 37(6):601 14 10386572
Forkner ME, Reardon TG, Carson GD Experimenting with feasibility of telemedicine in Alaska: successes and lessons learned Telemedicine Journal 1996 2(3):233 40 10165546
Frank AP, Wandell MG, Headings MD, et al Anonymous HIV testing using home collection and telemedicine counseling: a multicenter evaluation Archives of Internal Medicine 1997 157(3):309 14 9040298
Franken EA, Jr, Berbaum KS, Smith WL, et al. Teleradiology for consultation between practitioners and radiologists. Annals of the New York Academy of Sciences. 1992;670:277-80. [pmid: 1309098].
Franken EA, Jr, Berbaum KS, Smith WL, et al Teleradiology for rural hospitals: analysis of a field study Journal of Telemedicine & Telecare 1995 1(4):202 8 9375144
Franken EA, Jr, Whitten P, Smith WL Teleradiology services for a rural hospital: a case study Journal of Telemedicine & Telecare 1996 2(3):155 60 9375050
Franken EA, Jr, Berbaum KS, Brandser EA, et al Pediatric radiology at a rural hospital: value of teleradiology and subspecialty consultation American Journal of Roentgenology 1997 168(5):1349 52 9129442
Franken EA, Jr, Harkens KL, Berbaum KS Teleradiology consultation for a rural hospital: patterns of use Academic Radiology 1997 4(7):492 6 9232168
Freeman K, Wynn-Jones J, Groves-Phillips S, et al Teleconsulting: a practical account of pitfalls, problems and promise. Experience from the TEAM project group Journal of Telemedicine & Telecare 1996 2(Suppl 1):1 3 9375075
Friedman RH, Kazis LE, Jette A, et al A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control American Journal of Hypertension 1996 9(4 Pt 1):285 92 8722429
Friedman RH, Stollerman JE, Mahoney DM, et al The virtual visit: using telecommunications technology to take care of patients Journal of the American Medical Informatics Association 1997 4(6):413 25 61259 9391929
From science fiction to virtual reality Waitemata Health is a leader in telemedicine in New Zealand New Zealand Health & Hospital 1997 49(3):May Jun
Fuchs VR Health care for the elderly: how much? Who will pay for it? Health Affairs 1999 18(1):11 21 9926642
Fujita M, Suzuki Y, Takahashi M, et al The validity of intraoperative frozen section diagnosis based on video-microscopy (telepathology) General & Diagnostic Pathology 1995 141(2):105 10 8548590
Furth SL, Hwang W, Neu AM, et al For-profit versus not-for-profit dialysis care for children with end stage renal disease Pediatrics 1999 104(3 Pt 1):519 24 10469779
Furukawa M, Furukawa MK, Mizojiri G, et al Telemedicine in laryngology Telemedicine J 1998 4(4):329 33
Fyfe DA, Emge F, Johnson G, et al Clinical validation of digital image compression levels for fetal echocardiograms for telemedicine Echocardiography 1998 15(4):363 8 11175049
Gale ME, Vincent ME, Robbins AH Teleradiology for remote diagnosis: a prospective multi-year evaluation Journal of Digital Imaging 1997 10(2):47 50 9165418
Galvez J, Howell L, Costa MJ, et al Diagnostic concordance of telecytology and conventional cytology for evaluating breast aspirates Acta Cytologica 1998 42(3):663 7 9622684
Gammon D, Bergvik S, Bergmo T, et al Videoconferencing in psychiatry: a survey of use in northern Norway Journal of Telemedicine & Telecare 1996 2(4):192 8 9375058
Garner P, Collins M, Cameron K, et al Mobile telecare-a mobile support system to aid the provision of community-based care Journal of Telemedicine & Telecare 1996 2(Suppl 1):39 42 9375087
Garrett MK Telemedicine in Florida Journal of the Florida Medical Association 1997 84(2):81 2 9066227
Gelber H The experience of the Royal Children's Hospital Mental Health Service videoconferencing project Journal of Telemedicine & Telecare 1998 4(Suppl 1):71 3 9640744
Gilmour E, Campbell SM, Loane MA, et al Comparison of teleconsultations and face-to-face consultations: preliminary results of a United Kingdom multicentre teledermatology study British Journal of Dermatology 1998 139(1):81 7 9764153
Giovas P, Papadoyannis D, Thomakos D, et al Transmission of electrocardiograms from a moving ambulance Journal of Telemedicine & Telecare 1998 4(Suppl 1):5 7 9640717
Goh KY, Tsang KY, Poon WS Does teleradiology improve inter-hospital management of head-injury? Canadian Journal of Neurological Sciences 1997 24(3):235 9 9276110
Goh KY, Lam CK, Poon WS The impact of teleradiology on the inter-hospital transfer of neurosurgical patients British Journal of Neurosurgery 1997 11(1):52 6 9156019
Going E Telehealth in dialysis: the Simcoe County experience Cannt Journal 1998 8(3):36 8 9807326
Golant S The metropolitanization and suburbanization of the U.S. elderly population: 1970-1988 The Gerontologist 1990 30(1):80 5 2311965
Gold M, Siegel J, Russell L, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Goldberg M, Rosenthal D, Chew F, et al New high-resolution teleradiology system: prospective study of diagnosic accuracy in 685 transmitted clinical cases Radiology 1993 186(2):429 34 8421746
Goldberg MA, Sharif HS, Rosenthal DI, et al Making global telemedicine practical and affordable: demonstrations from the Middle East American Journal of Roentgenology 1994 163(6):1495 500 7992754
Goldschmidt L Telemedicine and information technology at the Veterans Administration Palo Alto Health Care System: serving patient care Effective Clinical Practice 1998 1(2):87 9 10187227
Gombas P, Szende B, Stotz G Support by telecommunication of decisions in diagnostic pathology. Experience with the first telepathology system in Hungary Orvosi Hetilap 1996 137(42):2299 303 8992427
Gomez EJ, del Pozo F, Quiles JA, et al. A telemedicine distributed system for cooperative medical diagnosis. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:433-7.
Gomez E, Poropatich R, Karinch MA, et al Tertiary telemedicine support during global military humanitarian missions Telemedicine Journal 1996 2(3):201 10 10165543
Gomez EJ, Del Pozo F, Hernando ME Telemedicine for diabetes care: the DIABTel approach towards diabetes telecare Medical Informatics 1996 21(4):283 95 9179833
Goncalves L, Cunha C Telemedicine project in the Azores Islands Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):285 7 8526570
Goodman DE, Feaster SJ, Kendall B, et al. Supported SelfCare successfully merges disease and case management using technology. In: HIMSS '98 Imagine the future: proceedings of the. 1998;1998:15-20.
Grad O, Hassol A, Gaumer G, et al Rural teleradiology: a snapshot Administrative Radiology Journal 1997 16(4-5):28 33 10169517
Gray J, Jones PC, Phillips M, et al. Telematics in the neonatal ICU and beyond: improving care for high-risk newborns and their families. Proceedings/AMIA Annual Fall Symposium. 1997:413-7.
Gray WP, Somers J, Buckley TF Report of a national neurosurgical teleradiology system Journal of Telemedicine & Telecare 1997 3(Suppl 1):36 7 9218377
Gray J, Pompilio-Weitzner G, Jones PC, et al. Baby CareLink: development and implementation of a WWW-based system for neonatal home telemedicine. Proceedings/AMIA Annual Symposium. 1998:351-5.
Gray J, Jones PC, Phillips M, et al Telematics in the neonatal ICU and beyond: improving care, communication and information sharing Medinfo 1998 9(Pt 1):294 7 10384465
Greek, Chicago hospitals link cardiology services Telemedicine & Virtual Reality 1997 2(12):
Greenland puts telemedicine server online Telemedicine & Virtual Reality 1998 3(4).
Grigsby J. Analysis of expansion of access to care through use of telemedicine and mobile health services. Report 2: Case Studies and current status of telemedicine.; 1994 1994.
Grigsby J, Kaehny MM, Sandberg EJ, et al Effects and effectiveness of telemedicine Health Care Financing Review 1995 17(1):115 31 10153466
Grigsby B 4th annual telemedicine program review. Part 2: United States Telemedicine Today 1997 5(4):30 8
Grigsby B, Brown N. 1998 Report on U. S. Telemedicine Activity. Portland, OR: Association of Telemedicine Service Providers; 1998.
Grigsby B. 2000. [pmcid: 384376].
Gropper A, Doyle S, Dreyer K Enterprise-scale image distribution with a Web PACS Journal of Digital Imaging 1998 11(3 Suppl 1):12 7 9735424
Gross DJ, Alecxih L, Gibson MJ, et al Out-of-pocket health spending by poor and near-poor elderly Medicare beneficiaries Health Services Research 1999 34(1 Pt 2):241 54 10199672 1088998
Group ITS. Report of the Interdisciplinary Telehealth Standards Group; 1998.
Group TSH. Issues and Opportunities Facing VHA Telemedicine: Reinventing Service To Patients. In: Telemedicine Strategic Healthcare Group; 1999.
Gulliford SM, Schneider JK, Jorgenson JA Using telemedicine technology for pharmaceutical services to ambulatory care patients American Journal of Health System Pharmacy 1512 55(14):1512 5 9676298
Guyatt G, Naylor C, Juniper E, et al User's guide to the medical literature. XII. How to use articles about health-related quality of life JAMA 1997(277):1232 7
Hagglund K, Clay DL Rural healthcare initiatives in spinal cord injury American Rehabilitation 1997 23(1):2 6
Halliday BE, Bhattacharyya AK, Graham AR, et al Diagnostic accuracy of an international static-imaging telepathology consultation service Human Pathology 1997 28(1):17 21 9013826
Halvorsen PA, Kristiansen IS Radiology services for remote communities: cost minimisation study of telemedicine British Medical Journal 1996 312(7042):1333 6 8646045
Halvorsen PA, Kristiansen IS Does teleradiography in primary health care reduce costs? An analysis based on utilization of radiographic examination in the municipality of Alta Tidsskrift for Den Norske Laegeforening 1997 117(11):1611 5 9198945
Hampton CL, Mazmanian PE, McCue MJ, et al Telemedicine in use. The Medical College of Virginia, The Powhatan Correctional Center and the Blackstone Family Practice Center Virginia Medical Quarterly 1996 123(3):167 70 8752956
Handels H, Busch C, Encarnacao J, et al KAMEDIN: a telemedicine system for computer supported cooperative work and remote image analysis in radiology Computer Methods & Programs in Biomedicine 1997 52(3):175 83 9051341
Handy-Williams B, Boyle M. A pilot study of the effects on patient outcome and resource utilization of the installation of a CT scanner and teleradiology system in a rural hospital [abstract]. AHSR & FHSR Annual Meeting Abstract Book. ;13:92-3.
Harris G Pacific Rim report: Japan Telemedicine Today 1998 6(6):18 9 10339347
Harrison R, Clayton W, Wallace P Can telemedicine be used to improve communication between primary and secondary care? British Medical Journal 1377 313(7069):1377 81 8956708
Harrison R, Clayton W, Wallace P Can telemedicine be used to improve communication between primary and secondary care? Bmj 1996 313(7069):1377 80 discussion 80-1 8956708
Harrison PV, Kirby B, Dickinson Y, et al Teledermatology-high technology or not? Journal of Telemedicine & Telecare 1998 4(Suppl 1):31 2 9640726
Hassol A, Gaumer G, Grigsby J, et al Rural telemedicine: a national snapshot Telemedicine Journal 1996 2(1):43 8 10165349
Hassol A Surprises from the rural telemedicine survey Telemedicine Today 1996 4(6):
Hassol A, Irvin C, Gaumer G, et al Rural applications of telemedicine Telemedicine Journal 1997 3(3):215 25 10174346
Haugen OA, Halvorsen TB, Aarset H, et al Telepathology in Mid-Norway Tidsskrift for Den Norske Laegeforening 1999 119(3):355 8 10074829
Hayes WS, Tohme WG, Komo D, et al A telemedicine consultative service for the evaluation of patients with urolithiasis Urology 1998 51(1):39 43 9457286
Haynes R, Ramsden M, McKibbon K, et al. A review of medical education and medical informatics. Academic Medicine. 1989;64:207-12. [pmid: 2647092].
Heautot JF, Gibaud B, Catroux B, et al Influence of the teleradiology technology (N-ISDN and ATM) on the inter-hospital management of neurosurgical patients Medical Informatics & the Internet in Medicine 1999 24(2):121 34 10399710
Heneghan C, Stern J, Sclafani AP, et al Can tele-otolaryngology help in screening for head and neck cancer? Telemedicine Today 1997 5(4):24 5 10174246
Hobbs FD, Bonnie. Current Population Reports, Special Studies, 65+ in the United States. Washington, DC: U.S. Bureau of the Census; 1996. Report No.: P23-190.
Home monitor reduces CHF readmissions... congestive heart failure Case Management Advisor 1997 8(3).
Homma S, Ishikawa Y, Sato M, et al Clinical evaluations of a telemedicine system for elderly patients Japan Journal of Medical Informatics 1998 18(1):39 47
Houston M, Myers J, Levens S, et al Clinical consultations using store-and-forward telemedicine technology Mayo Clinic Proceedings 1999 74(8):764 9 10473351
Hawaii uses telemedicine to link islands, mainland, region Telemedicine & Virtual Reality 1997 2(12):
Hawaiian Airlines flies with MedLink for round-the-clock medical assistance services Telemedicine & Virtual Reality 1997 2(11).
HCFA issues payment instructions for teleconsultations in rural HPSAs (health professional shortage areas) Patient Accounts 1999 22(5).
Home telemedicine identifies innovations Telemedicine & Virtual Reality 1998 3(12):135 6
Houtchens BA, Clemmer TP, Holloway HC, et al Telemedicine and international disaster response. Medical consultation to Armenia and Russia via a telemedicine spacebridge Prehospital & Disaster Medicine 1993 8(1):57 66
Hoyle MF, Jamieson LN Use of slowscan technology in the North Slope Borough Telehealth Project International Journal of Technology Assessment in Health Care 1989 5(1):63 71 10292543
Hripcsak G, Knirsch CA, Jain NL, et al A health information network for managing innercity tuberculosis: bridging clinical care, public health, and home care Computers & Biomedical Research 1999 32(1):67 76 10066356
Hubble JP, Pahwa R, Michalek DK, et al Interactive video conferencing: a means of providing interim care to Parkinson's disease patients Movement Disorders 1993 8(3):380 2 8341308
Hunt D, Haynes R, Hanna S, et al. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review. Journal of the American Medical Association. 1998;280:1339-46. [pmid: 9794315].
Huston JL, Burton DC Patient satisfaction with multispecialty interactive teleconsultations Journal of Telemedicine & Telecare 1997 3(4):205 8 9614735
Hutchinson JR Back to the future: telemedicine in Georgia Journal of the Medical Association of Georgia 1996 85(1):23 6 8583183
Imaging company creates retina telemedicine network Telemedicine & Virtual Reality 1997 2(1).
Inada H, Horio H, Nakazawa K, et al A study on home health care support information system for health evaluation Journal of Medical Systems 1998 22(2):69 75 9571513
Inada H, Horio H, Nakazawa K, et al A study on development of a home health care support information system Medinfo 1998 9(Pt 1):269 71 10384459
Interactive video program cuts home care costs while slashing readmission rates Healthcare Demand & Disease Management 1998 4(3):46 8 10181085
Itzhak B, Weinberger T, Berkovitch E, et al Telemedicine in primary care in Israel Journal of Telemedicine & Telecare 1998 4(Suppl 1):11 4 9640719
Iwashyna TJ, Zhang JX, Lauderdale DS, et al A methodology for identifying married couples in Medicare data: mortality, morbidity, and health care use among the married elderly Demography 1998 35(4):413 9 9850466
Jacobs P, Hall E, Henderson I, et al Episodic acute care costs: linking inpatient and home care Canadian Journal of Public Health Revue Canadienne de Sante Publique 1995 86(3):200 5 7671208
Jaeschke R, Guyatt G, Sackett D, et al. User's guide to the medical literature. III. How to use an article about a diagnostic test. Are the results of the study valid?. JAMA. 1994;271:389-91. [pmid: 8283589].
Japanese hospital links to Belarus Clinic Telemedicine & Virtual Reality 1998 3(10).
Japsen B Oklahoma network in link with state telemedicine group Modern Healthcare 1996 26(41):
Japsen B House calls. Kansas hospital's experiment in home health telemedicine cuts costs, visits Modern Healthcare 1998 28(12):
Jarris RF, Jr Satellite video system aids offshore treatment Health Management Technology 1994 15(4):32 4 10132635
Jefferson L Telemedicine: saving lives & costs in the Lone Star State Healthcare Informatics 1994 11(11):40 2 10138392
Jennett PA, Hall WG, Morin JE, et al Evaluation of a distance consulting service based on interactive video and integrated computerized technology Journal of Telemedicine & Telecare 1995 1(2):69 78 9375123
Jennett PA, Watanabe M, Hall WG The use of advanced computer technology to enhance access to health care and to respond to community needs: the results of the evaluation of a technology-based clinical consultation service Medinfo 1995 8(Pt 2):1479 81 8591478
Jerrold L Litigation, legislation, and ethics. The problem, electronic data transmission and the law American Journal of Orthodontics & Dentofacial Orthopedics 1998 113(4):478 9 9563366
Johnson P, Andrews DC Remote continuous physiological monitoring in the home Journal of Telemedicine & Telecare 1996 2(2):107 13 9375071
Johnson RE, Goodman MJ, Hornbrook MC, et al The effect of increased prescription drug cost-sharing on medical care utilization and expenses of elderly health maintenance organization members Medical Care 1997 35(11):1119 31 9366891
Johnson MA, Davis P, McEwan AJ, et al Preliminary findings from a teleultrasound study in Alberta Telemedicine Journal 1998 4(3):267 76 9831751
Johnson P The clinical and economic advantages of remote, community-based physiological assessment Journal of Telemedicine & Telecare 1998 4(Suppl 1):64 6 9640741
Johnston B, Wheeler L, Deuser J Kaiser Permanente Medical Center's pilot Tele-Home Health Project Telemedicine Today 1997 5(4):16 7 10174243
Johnston B, Wheeler L, Deuser J, et al Outcomes of the Kaiser Permanente Tele-Home Health Research Project Archives of Family Medicine 2000 Volume 9(January, 2000):40 5 10664641
Jones DH, Crichton C, Macdonald A, et al Teledermatology in the Highlands of Scotland Journal of Telemedicine & Telecare 1996 2(Suppl 1):7 9 9375077
Jones BN, 3rd, Colenda CC Telemedicine and geriatric psychiatry Psychiatric Services 1997 48(6):783 5 9175185
Kagetsu NJ, Zulauf DR, Ablow RC Clinical trial of digital teleradiology in the practice of emergency room radiology Radiology 1987 165(2):551 4 3659383
Kaiser patients accept telemedicine Telemedicine & Virtual Reality 1998 3(3).
Kane RL, Friedman B State variations in Medicare expenditures [published erratum appears in Am J Public Health 1997 Dec;87(12):2052] American Journal of Public Health 1997 87(10):1611 9 9357341 1381122
Kayser K, Drlicek M Visual telecommunication for expert consultation of intraoperative sections Zentralblatt fur Pathologie 1992 138(6):395 8 1297430
Kayser K, Fritz P, Drlicek M, et al Expert consultation by use of telepathology-the Heidelberg experiences Analytical Cellular Pathology 1995 9(1):53 60 7577755
Keating NL, Zaslavsky AM, Ayanian JZ Physicians' experiences and beliefs regarding informal consultation [see comments] Journal American Medical Association 1998 280(10):900 4
Keating NL, Zaslavsky AM, Ayanian JZ Physicians' experiences and beliefs regarding informal consultation Jama 1998 280(10):900 4 9739974
Kehler M, Bengtsson PO, Freitag M, et al Radiological videoconferencing in Sweden Journal of Telemedicine & Telecare 1996 2(3):161 4 9375051
Keith R, Granger C, Hamilton B, et al. The functional independence measure: A new tool for rehabilitation. In: Eisenberg M, Grzesiak R, editors. Advances in Clinical Rehabilitation. New York: Springer-Verlag; 1987.
Kesler C, Balch D Development of a telemedicine and distance learning network in rural eastern North Carolina Journal of Telemedicine & Telecare 1995 1(3):178 82 9375139
Kincade K MediCal devises pay policy for California telemedicine consults Telemedicine & Telehealth Networks 1998 4(2):11 2 10181479
King BF, Jr, Erickson BJ, Williamson B, Jr, et al Electronic imaging and clinical implementation: work group approach at Mayo Clinic, Rochester Journal of Digital Imaging 1999 12(2 Suppl 1):32 6 10342160
Kinsella A Ask Home Healthcare Nurse. Telehealth and home care nursing Home Healthcare Nurse 1997 15(11):796 7 9418431
Kirkpatrick AW, Brenneman FD, McCallum A, et al Prospective evaluation of the potential role of teleradiology in acute interhospital trauma referrals Journal of Trauma Injury Infection & Critical Care 1017 46(6):1017 23
Kirkpatrick AW, Brenneman FD, McCallum A, et al Prospective evaluation of the potential role of teleradiology in acute interhospital trauma referrals Journal of Trauma-Injury Infection & Critical Care 1999 46(6):1017 23
Klercker TA, Trell E Ambulatory otorhinolaryngologic care in general practice on an inter/intranet utilising World Wide Web tools Oto Rhino Laryngologia Nova 1997 7(4):169 77
Knorr JR, Ragland RL, Stark DD Teleradiology: experiences with magnetic resonance imaging using this new technology Journal of the American Osteopathic Association 1998 98(2):97 101 9509836
Kofos D, Pitetti R, Orr R, et al Telemedicine in pediatric transport: a feasibility study Pediatrics 1998 102(5):
Komisar HL, Hunt-McCool J, Feder J Medicare spending for elderly beneficiaries who need long-term care Inquiry 1997 34(4):302 10 9472229
Kormano M, Kallio T, Heinila J Teleradiology in Turku University Hospital-diagnostic evaluation and clinical applications Computer Methods & Programs in Biomedicine 1994 43(1-2):125 8 7956134
Korsoff L, Kallio T, Kormano M, et al Experiences with a teleradiology system in pulmonary diseases Acta Radiologica 1995 36(1):37 40 7833166
Kottke TE, Finger LL, Trapp MA, et al The Pine Ridge-Mayo National Aeronautics and Space Administration telemedicine project: program activities and participant reactions Mayo Clinic Proceedings 1996 71(4):329 37 8637254
Kouides RW, Bennett NM, Lewis B, et al Performance-based physician reimbursement and influenza immunization rates in the elderly. The Primary-Care Physicians of Monroe County American Journal of Preventive Medicine 1998 14(2):89 95 9631159
Kristiansen IS, Halvorsen PA. Will the introduction of tele-radiologic services be cost saving? [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care.
Krotz D Remote ultrasound reading earns its keep in Seattle. Suburban patients avoid travel to downtown hospitals Diagnostic Imaging 1997 19(8).
Krug telemedicine system flies aboard space shuttle Telemedicine & Virtual Reality 1998 3(3):
Krupinski E, Maloney K, Hopper L, et al Evaluation of radiologist performance using telemedicine services Journal of Digital Imaging 1997 10(3 Suppl 1):83 5 9268847
Krupinski EA, McNeill K, Ovitt TW, et al Patterns of use and satisfaction with a university-based teleradiology system Journal of Digital Imaging 1999 12(2 Suppl 1):166 7 10342201
Krupinski E, LeSueur B, Ellsworth L, et al Diagnostic Accuracy and Image Quality using a digital camera for teledermatology Telemedicine Journal 1999 5(3).
Kudo T The experimental study on teleradiology system using HDTV and ISDN Hokkaido Igaku Zasshi - Hokkaido Journal of Medical Science 1995 70(6):807 16
Kuhrik N, Kuhrik M, Williams J, et al Defibrillation over the phone American Journal of Nursing 1992 92(11):28 31 1485627
Kulik JF, de la Tribonniere X, Bricon-Souf N, et al. Telemedicine for AIDS patients accommodations. Proceedings/AMIA Annual Fall Symposium. 1997:379-82.
Kunkler IH, Rafferty P, Hill DM, et al Telemedicine. Proved acceptable in pilot study in oncology in Scotland [letter] Bmj 1997 314(7079):
Kunkler IH, Rafferty P, Hill D, et al A pilot study of tele-oncology in Scotland Journal of Telemedicine & Telecare 1998 4(2):113 9 9744168
Kuo D, Gifford DR, Stein MD Curbside consultation practices and attitudes among primary care physicians and medical subspecialists [see comments] Journal American Medical Association 1998 280(10):905 9
Kuo D, Gifford DR, Stein MD Curbside consultation practices and attitudes among primary care physicians and medical subspecialists Jama 1998 280(10):905 9 9739975
Kuo RL, Aslan P, Dinlenc CZ, et al Secure transmission of urologic images and records over the Internet Journal of Endourology 1999 13(3):141 6 10360490
Kuttner R The American health care system. Health insurance coverage New England Journal of Medicine 1999 340(2):163 8 9887170
Kvedar JC, Edwards RA, Menn ER, et al. The Substitution of Digital Images for Dermatologic Physical Examination. Archives of Dermatology. 1997;133:161-7. [pmid: 9041828].
Kvist M. Telemedicine applications in Finland 1996. Helsinki: FinOHTA 1996;45.
Lamb A, Eydmann M, Boddy K Remote maternity clinics British Journal of Healthcare Computing & Information Management 1997 14(7):22 4
Lambrecht CJ Emergency physicians' roles in a clinical telemedicine network Annals of Emergency Medicine 1997 30(5):670 4 9360579
Lambrecht CJ Telemedicine in trauma care: description of 100 trauma teleconsults Telemedicine Journal 1997 3(4):265 8 10176007
Lambrecht CJ, Canham WD, Gattey PH, et al. Telemedicine and orthopaedic care. A review of 2 years of experience. Clinical Orthopaedics & Related Research. 1998;(348):228-32. [pmid: 9553557].
Lamminen H, Nevalainen J, Alho A, et al Experimental telemedicine in orthopaedics Journal of Telemedicine & Telecare 1996 2(3):170 3 9375053
Landwehr JB, Jr., Zador IE, Wolfe HM, et al Telemedicine and fetal ultrasonography: assessment of technical performance and clinical feasibility American Journal of Obstetrics & Gynecology 1997 177(4):846 8 9369831
Lareng L Telemedicine in Europe Urgences Medicales 1992 11(3-4):147 8
Larson A, Lynch DA, Zeligman B, et al Accuracy of diagnosis of subtle chest disease and subtle fractures with a teleradiology system American Journal of Roentgenology 1998 170(1):19 22 9423590
Lattimer V, Sassi F, George S, et al Cost analysis of nurse telephone consultation in out of hours primary care: evidence from a randomised controlled trial British Medical Journal 2000 320(15 April):1053 7 27349 10764368
Laulund T, Hojlund AP, Frandsen P, et al Patient consultation via broad-band network-pilot project in hand surgery Nordisk Medicin 1995 110(8-9):211 2 7478970
Lawrence LP Focus on technology. Hundreds of miles in a split second PT Magazine of Physical Therapy 1998 6(10):46 9
Lee AJ, Gehlbach S, Hosmer, et al Medicare treatment differences for blacks and whites Medical Care 1997 35(12):1173 89 9413306
Lee BR, Bishoff JT, Janetschek G, et al A novel method of surgical instruction: international telementoring World Journal of Urology 1998 16(6):367 70 9870280
Lee BR, Caddedu JA, Janetschek G, et al. International surgical telementoring: our initial experience. Studies in Health Technology & Informatics. 1998;50:41-7. [pmid: 10180584].
Lee JK, Renner JB, Saunders BF, et al Effect of real-time teleradiology on the practice of the emergency department physician in a rural setting: initial experience Academic Radiology 1998 5(8):533 8 9702263
Lee BR, Allaf M, Moore R, et al Clinical decision making using teleradiology in urology American Journal of Roentgenology 1999 172(1):19 22 9888731
Lehmann ED, Deutsch T Application of computers in diabetes care - A review. I. Computers for data collection and interpretation Medical Informatics 1995 20(4):281 302 8744938
Lehmann ED, Deutsch T Application of computers in diabetes care - A review. II. Computers for decision support and education Medical Informatics 1995 20(4):303 29 8744939
Lehmann ED Application of computers in clinical diabetes care Diabetes, Nutrition & Metabolism Clinical & Experimental 1997 10(2):45 59
Lehmann KJ, Walz M, Bolte R, et al Possible applications of the KAMEDIN teleradiology system with special reference to an economic analysis Radiologe 1997 37(4):278 84 9265212
Lehoux P, Battista RN, Lance JM Is HTA ready for the assessment of telemedicine? [abstract] Annual Meeting of International Society of Technology Assessment in Health Care 1998 14(97).
Leisch E, Tsiknakis M, Orphanoudakis SC. Pre-hospital health emergency management as an integrated service of the Regional Health Telematics Network of Crete. Studies in Health Technology & Informatics. 1997;43:33-7. [pmid: 10179566].
Lemaire ED, Jeffreys Y Low-bandwidth telemedicine for remote orthotic assessment Prosthetics & Orthotics International 1998 22(2):155 67 9748001
Lenane JC High-tech cardiac home care. An emerging delivery system Caring 1994 13(2):28 31 10132226
Lesher JL, Jr, Davis LS, Gourdin FW, et al Telemedicine evaluation of cutaneous diseases: a blinded comparative study Journal of the American Academy of Dermatology 1998 38(1):27 31 9448201
Levine BA, Cleary KR, Norton GS, et al Experience implementing a DICOM 3.0 multivendor teleradiology network Telemedicine Journal 1998 4(2):167 75 9710649
Levine SR, Gorman M "Telestroke" : the application of telemedicine for stroke Stroke 1999 30(2):464 9 9933289
Lewis A Telemedicine is the future, but when will it arrive? Remington Report 1997 5(5):4 6
Lewis P, McCann R, Hidalgo P, et al Use of store and forward technology for vascular nursing teleconsultation service Journal of Vascular Nursing 1997 15(4):116 23 9429380
Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnostic tests JAMA 1999 282(11):1061 6 10493205
Lilford RJ, Braunholtz DA, Greenhalgh R, et al Trials and fast changing technologies: the case for tracker studies Bmj 2000 320(7226):43 6 10617532 1117318
Lindberg CC Implementation of in-home telemedicine in rural Kansas: answering an elderly patient's needs Journal of the American Medical Informatics Association 1997 4(1):14 7 61193 8988469
Ling R Telemedicine: treating the patient by remote control Journal of the Royal Naval Medical Service 1993 79(3):145 7 8207707
Litwin MS, Pasta DJ, Stoddard ML, et al Epidemiological trends and financial outcomes in radical prostatectomy among Medicare beneficiaries, 1991 to 1993 Journal of Urology 1998 160(2):445 8 9679895
Liu CT, Lin CC, Wong JM, et al Design and evaluation of a telediagnosis system Biomedical Engineering Applications Basis Communications 1997 9(2):52 60
Liu K, Wissoker D, Rimes C Determinants and costs of Medicare post-acute care provided by SNFs and HHAs Inquiry 1998 35(1):49 61 9597017
Liu Y, Wang L Telemedicine in border area of China Telemedicine J 1998 4(1):39 41
Loane MA, Corbett R, Bloomer SE, et al Diagnostic accuracy and clinical management by realtime teledermatology. Results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial Journal of Telemedicine & Telecare 1998 4(2):95 100 9744165
Loane MA, Bloomer SE, Corbett R, et al Patient satisfaction with realtime teledermatology in Northern Ireland Journal of Telemedicine & Telecare 1998 4(1):36 40 9640708
Loane MA, Gore HE, Bloomer SE, et al Preliminary results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial: is clinical management by realtime teledermatology possible? Journal of Telemedicine & Telecare 1998 4(Suppl 1):3 5 9640716
Loane M, Wootton R. Cost-effectiveness in telemedicine[abstract]. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999 June 6-10; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 68.
Loane MA, Bloomer SE, Corbett R, et al Patient cost-benefit analysis of teledermatology measured in a randomized control trial Journal of Telemedicine & Telecare 1999 5(Suppl 1):S1 3 10534821
Loane M, Bloomer S, Corbett R, et al A randomized controlled trial to assess the clinical effectiveness of both realtime and store-and-forward teledermatology compared with conventional care Journal of Telemedicine and Telecare 2000 6(Supplement 1):S1 3 10793956
London JW, Morton DE, Marinucci D, et al. Cost effective Internet access and video conferencing for a community cancer network. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:781-4.
London JW, Morton DE, Marinucci D, et al. Telemedicine case study: using desktop personal videoconferencing for consultations between physicians in a community cancer network. In: Toward an electronic patient record '97: proceedings. 1997;1997:260-5.
London JW, Morton DE, Marinucci D, et al The implementation of telemedicine within a community cancer network Journal of the American Medical Informatics Association 1997 4(1):18 24 61194 8988470
Lorton L, Legler JD A telemedicine trial Journal of Ahima 1996 67(4):40 2 10155779
Loula P, Rauhala E, Erkinjuntti M, et al Distributed clinical neurophysiology Journal of Telemedicine & Telecare 1997 3(2):89 95 9206279
Lowitt MH, Kessler, II, Kauffman CL, et al Teledermatology and in-person examinations: a comparison of patient and physician perceptions and diagnostic agreement Archives of Dermatology 1998 134(4):471 6 9554300
Ludwig K, Bick U, Oelerich M, et al Is image selection a useful strategy to decrease the transmission time in teleradiology? A study using 100 emergency cranial CTs European Radiology 1998 8(9):1719 21 9866793
Lugg DJ Telemedicine: have technological advances improved health care to remote Antarctic populations? International Journal of Circumpolar Health 1998 57(Suppl 1):682 5 10093367
Lyon CC, Harrison PV Digital imaging and teledermatology: educational and diagnostic applications of a portable digital imaging system for the trainee dermatologist Clinical & Experimental Dermatology 1997 22(4):163 5 9499603
Lyttle J Fibre-optic links eliminate distances separating specialists, patients Cmaj 1998 158(10):1349 50 9614831 1229334
Maass M, Kosonen M, Kormano M. Outcomes of a teleneuroradiological consultation network with Turku University central hospital and three regional hospitals[abstract]. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999 June 6-10; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 78.
Maclean JR, Brebner JA, Norman JN A review of Scottish telemedicine Journal of Telemedicine & Telecare 1995 1(1):1 6 9375111
Magnusson L, Berthold H, Chambers M, et al Using telematics with older people: the ACTION project. Assisting Caregivers using Telematics Interventions to meet older persons' needs Nursing Standard 1998 13(5):36 40 9919185
Mahmud K, Lenz J The personal telemedicine system. A new tool for the delivery of health care Journal of Telemedicine & Telecare 1995 1(3):173 7 9375138
Mahoney DF, Tarlow B, Sandaire J A computer-mediated intervention for Alzheimer's caregivers Computers in Nursing 1998 16(4):208 16 quiz 17-8 9675988
Maine area ties up to telemedicine project Telemedicine & Virtual Reality 1998 3(10).
Malani J, Dever GJ Telemedicine demonstration projects in the Western Pacific Journal of Telemedicine & Telecare 1997 3(Suppl 1):43 6 9218380
Malone FD, Nores JA, Athanassiou A, et al Validation of fetal telemedicine as a new obstetric imaging technique American Journal of Obstetrics & Gynecology 1997 177(3):626 31 9322634
Malone FD, Athanassiou A, Craigo SD, et al Cost issues surrounding the use of computerized telemedicine for obstetric ultrasonography Ultrasound in Obstetrics & Gynecology 1998 12(2):120 4 9744057
Manchanda M, McLaren P Cognitive behaviour therapy via interactive video Journal of Telemedicine & Telecare 1998 4(Suppl 1):53 5 9640736
Mandil SH Telematics in health care in developing countries Journal of Medical Systems 1995 19(2):195 203 7602252
Manni C Actual state of telemedicine in Italy and possible development Rivista di Neurobiologia 1994 40(5-6):543 9
Mannion L, Fahy TJ, Duffy C, et al Telepsychiatry: an island pilot project Journal of Telemedicine & Telecare 1998 4(Suppl 1):62 3 9640740
Manson N Telemedicine and the New Children's Hospital (Royal Alexandra Hospital for Children) Journal of Telemedicine & Telecare 1997 3(Suppl 1):46 8 9218381
Marano P, Vincenzoni M, Campioni P Medical teleconsultation: data of our experience with Telecos Rivista di Neurobiologia 1994 40(5-6):537 41
Marcus DM, Brooks SE, Ulrich LD, et al Telemedicine diagnosis of eye disorders by direct ophthalmoscopy A pilot study. Ophthalmology 1998 105(10):1907 14
Marrero DG, Vandagrief JL, Kronz K, et al Using telecommunication technology to manage children with diabetes: The computer-linked outpatient clinic (CLOC) study The Diabetes Educator 1995 21(4):313 19 7621734
Martin E, Dusserre P, Fages A, et al Telepathology: a new tool of pathology? Presentation of a French national network Zentralblatt fur Pathologie 1992 138(6):419 23 1297435
Martin E, Dusserre P, Got C, et al Telepathology in France. Justifications and developments Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):191 5 8526550
Martin E HCFA's pay policy hampering telemedicine programs ACP-ASIM Observer 2000(February):4 5
Martinez R, Chimiak W, Kim J, et al The Rural and Global Medical Informatics Consortium and Network for Radiology Services Computers in Biology & Medicine 1995 25(2):85 106 7554847
Mattioli L, Goertz K, Ardinger R, et al Pediatric cardiology: auscultation from 280 miles away Kansas Medicine 1992 93(12):326, 47 50
Mavrogeni S, Sotiriou D, Thomakos D, et al Telecardiology services in the Aegean islands Journal of Telemedicine & Telecare 1996 2(Suppl 1):74 6 9375099
Mavrogeni S, Tsirintani M, Kokkinos D. Urgent response telecardiology services and training-collaboration between Onassis Cardiac Surgery Hospital and Aegian Islands' Health Care Centers. Studies in Health Technology & Informatics. 1997;43:902-5. [pmid: 10179799].
McBean AM, Turner CF, Fitterman LK, et al Monitoring the health status and impact of treatment on Americans: the Medicare Beneficiary Health Status Registry Medical Care 1999 37(2):189 203 10024123
McCormack J Innovators 1998. Making eye care more accessible Health Data Management 1998 6(7):40 2
McCue MJ, Mazmanian PE, Hampton C, et al The case of Powhatan Correctional Center/Virginia Department of Corrections and Virginia Commonwealth University/Medical College of Virginia Telemedicine Journal 1997 3(1):11 7 10166440
McCue MJ, Mazmanian PE, Hampton CL, et al Cost-minimization analysis: a follow-up study of a telemedicine program Telemedicine J 1998 4(4):323 7
McIntosh WA, Alston L, Booher R, et al Time spent with patients and charges to patients using telemedicine for specialty consultations [abstract] Abstract Book/Association for Health Services Research ;1540.
McKee JJ, Evans NE, Owens FJ Digital transmission of 12-lead electrocardiograms and duplex speech in the telephone bandwidth Journal of Telemedicine & Telecare 1996 2(1):42 9 9375041
McLaren P, Ball CJ, Summerfield AB, et al An evaluation of the use of interactive television in an acute psychiatric service Journal of Telemedicine & Telecare 1995 1(2):79 85 9375124
McLaren P, Ball CJ Telemedicine: lessons remain unheeded British Medical Journal 1995 310(6991):1390 1 7787547
McLaren PM, Blunden J, Lipsedge ML, et al Telepsychiatry in an inner-city community psychiatric service Journal of Telemedicine & Telecare 1996 2(1):57 9 9375043
McNeill KM, Weinstein RS, Holcomb MJ Arizona Telemedicine Program: implementing a statewide health care network Journal of the American Medical Informatics Association 1998 5(5):441 7 61325 9760392
Meadows MT, Davis C What works. Telemedicine team work cuts transfer costs and generates new revenue Health Management Technology 1998 19(11).
Medicare begins telemedicine coverage Case Management Advisor 1997 8(10).
Mekhjian H, Warisse J, Gailiun M, et al An Ohio telemedicine system for prison inmates: a case report Telemedicine Journal 1996 2(1):17 24 10165346
Meltzer B Telemedicine in emergency psychiatry Psychiatric Services 1997 48(9):1141 2 9285973
Melzer SM, Poole SR Computerized pediatric telephone triage and advice programs at children's hospitals: operating and financial characteristics Archives of Pediatrics & Adolescent Medicine 1999 153(8):858 63 10437761
Mertz M, Mann G, Zahlmann G, et al Scientific role of German ophthalmology in the European telecommunication project OPHTEL Ophthalmologe 1997 94(7):523 8 9333401
Miaoulis G, Protopapa E, Skourlas C, et al Telepathology in Greece. Experience of the Metaxas Cancer Institute Zentralblatt fur Pathologie 1992 138(6):425 8 1297436
Miaoulis G, Protopapa E, Skourlas C, et al Supporting telemicroscopy and laboratory medicine activities the Greek 'TELE. INFO. MED. LAB' project Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):275 81 8526568
Miller PZ Home monitoring for congestive heart failure patients Caring 1995 14(8):53 4 10151219
Millman M, editor. Access to Health Care in America. Washington, DC: National Academy Press; 1993.
Mintzer CL, Wasem CJ, Puskin DS Program activity in the second year of the Rural Telemedicine Grant Program. Part 1 Telemedicine Today 1997 5(5):35 9 10174342
Mintzer CL, Wasem CJ, Puskin DS Program activity in the second year of the Rural Telemedicine Grant Program Part 2 Telemedicine Today 1997 5(6):32 3 10176388
Mitchell BR, Mitchell JG, Disney AP User adoption issues in renal telemedicine Journal of Telemedicine & Telecare 1996 2(2):81 6 9375067
Mitchell JG, Disney AP Clinical applications of renal telemedicine Journal of Telemedicine & Telecare 1997 3(3):158 62 9489111
Mitchell J Telemedicine industry in Australia: case study of existing and emerging opportunities Telemedicine J 1998 4(2):187 91
Mixing tech and touch saves $427 a month Cost Management in Cardiac Care 1997 2(12):144 6
Mixing tech and touch saves $427 a month Hospital Peer Review 1998 23(1):15 6 10175810
Mixing tech and touch saves $427 a month... telemedicine with human intervention Disease State Management 1998 4(3):27 8
Miyasaka K, Suzuki Y, Sakai H, et al Interactive communication in high-technology home care: videophones for pediatric ventilatory care Pediatrics 1997 99(1):
Moncrief JW, Sorrels PA. Primary care and hemodialysis monitoring through telemedicine. Studies in Health Technology & Informatics. 1996;29:250-4. [pmid: 10163757].
Moncrief JW Telemedicine in the care of the end-stage renal disease patient Advances in Renal Replacement Therapy 1998 5(4):286 91 9792083
Moncur JT, Rosen JM, Zhu S, et al. Medical electronic link (MEL): providing telemedicine on the World Wide Web. Studies in Health Technology & Informatics. 1997;39:328-33. [pmid: 10168928].
Montani C, Billaud N, Couturier P, et al "Telepsychometry": a remote psychometry consultation in clinical gerontology: preliminary study Telemedicine Journal 1996 2(2):145 50 10165357
Montani C, Billaud N, Tyrrell J, et al Psychological impact of a remote psychometric consultation with hospitalized elderly people Journal of Telemedicine & Telecare 1997 3(3):140 5 9489108
Montani S, Bellazzi R, Larizza C, et al Protocol-based reasoning in diabetic patient management International Journal of Medical Informatics 1999 53(1):61 77 10075131
Moore RG, Adams JB, Partin AW, et al Telementoring of laparoscopic procedures: initial clinical experience Surgical Endoscopy 1996 10(2):107 10 8932609
Morgan J, Cairns, Tremblay, et al. Quo vadimus? Telemedicine in Wales - A personal view. Round Table Series, Royal Society of Medicine. 1996;41:(pp 50-53).
Morrissey J How telemedicine eased ER's burden Modern Healthcare 1996 26(14):47 8 10157112
Moses PL, McGowan JJ, Ricci MA. Efficacy of tele-endoscopy in a rural capitated market. Proceedings/AMIA Annual Fall Symposium. 1997:398-402.
Mozambique telemedicine link inaugurated Telemedicine & Virtual Reality 1998 3(4).
Mullick FG, Fontelo P, Pemble C Telemedicine and telepathology at the Armed Forces Institute of Pathology: history and current mission Telemedicine Journal 1996 2(3):187 93 10165541
Mun SK, Levine B, Cleary K, et al Deployable teleradiology and telemedicine for the US military Computer Methods & Programs in Biomedicine 1998 57(1-2):21 7 9803994
Murdison KA Telemedicine: a useful tool for the pediatric cardiologist Telemedicine Journal 1997 3(2):179 84 10168283
Myhill K Telepsychiatry in rural South Australia Journal of Telemedicine & Telecare 1996 2(4):224 5 9375063
Naef RW, 3rd, Perry KG, Jr., Magann EF, et al Home blood pressure monitoring for pregnant patients with hypertension Journal of Perinatology 1998 18(3):226 9 9659655
Nagase T, Kaihara S, Hasegawa T, et al A visual telemedicine system by means of the integration of ordinary TV and HDTV still image transmission Japan Journal of Medical Informatics 1997 17(3):373 7
Nakamura K, Takano T, Akao C The effectiveness of videophones in home healthcare for the elderly Medical Care 1999 37(2):117 25 10024116
[No authors listed] Naval telemedicine: fleet lines up to provide live teleconsulting Telemedicine & Virtual Reality 1998 3(4)
Northern Arizona area expands telepsychiatry services Telemedicine & Virtual Reality 1998 3(6).
Nova Scotia sets up province-wide network Telemedicine & Virtual Reality 1998 3(1):
Nepal sets up telepsychiatry program Telemedicine & Virtual Reality 1998 3(4):
New VA facility creates telemedicine-friendly atmosphere Telemedicine & Virtual Reality 1997 2(8):85 6
Navein J, Hagmann J, Ellis J Telemedicine in support of peacekeeping operations overseas: an audit Telemedicine Journal 1997 3(3):207 14 10174345
Navein J, Fisher A, Geiling J, et al Portable satellite telemedicine in practice Journal of Telemedicine & Telecare 1998 4(Suppl 1):25 8 9640724
Neumann ME Telemedicine project looks to improve ESRD care, lower costs. TRC/Georgetown University Medical Center begin two-year experiment Nephrology News & Issues 1997 11(10):67 9 9391397
New guide discusses telemedicine for the home Telemedicine & Virtual Reality 1998 3(3).
NIIT (National Information Infrastructure Testbed) update: Denver Health and Hospitals links rural areas Health Management Technology 1996 17(6).
Nitzkin JL, Zhu N, Marier RL Reliability of telemedicine examination Telemedicine Journal 1997 3(2):141 57 10168280
Nordrum I, Eide TJ Remote frozen section service in Norway Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):253 6 8526562
Nores J, Athanassiou A, Malone FD, et al Technical dependability of obstetric ultrasound transmission via ISDN Telemedicine Journal 1997 3(3):191 5 10174343
Nores J, Malone FD, Athanassiou A, et al Validation of first-trimester telemedicine as an obstetric imaging technology: a feasibility study Obstetrics & Gynecology 1997 90(3):353 6 9277643
Noro R, Hubaux JP, Meuli R, et al Real-time telediagnosis of radiological images through an asynchronous transfer mode network: the ARTeMeD project Journal of Digital Imaging 1997 10(3 Suppl 1):116 21 9268855
Norton SA, Floro C, Bice SD, et al Telemedicine in Micronesia Telemedicine Journal 1996 2(3):225 31 10165545
Norton SA, Burdick AE, Phillips CM, et al Teledermatology and underserved populations Archives of Dermatology 1997 133(2):197 200 9041833
Nova Scotia Telemedicine Project Telemedicine Today 1997 5(2):Mar Apr
Nsa W, Bratzler DW, Millar JS Characteristics and hospital utilization of the Oklahoma Medicare population: 1994-1996 Journal - Oklahoma State Medical Association 1998 91(2):60 7 9583320
O'Hanley P Triage through technology: New Brunswick Tele-Care service reduces ER visits Hospital Quarterly 1997 1(2):46 7 10345291
O'Hare NJ, Wallis F, Kennedy JM, et al Specification and initial evaluation of a multiple application teleradiology system British Journal of Radiology 1996 69(824):735 42 8949676
Oakley A, Duffill M, Astwood D, et al Melanoma-diagnosis by telemedicine Journal of Telemedicine & Telecare 1996 2(3):174 5 9375054
Oakley AM, Astwood DR, Loane M, et al Diagnostic accuracy of teledermatology: results of a preliminary study in New Zealand New Zealand Medical Journal 1997 110(1038):51 3 9076285
Oakley AM, Duffill MB, Reeve P Practising dermatology via telemedicine New Zealand Medical Journal 1998 111(1071):296 9 9760955
Ohinmaa A, Reponen J, Mielonen ML, et al. Economic evaluation of telemedicine in northern Finland [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. ;13.
Ohinmaa A, Reponen J. A model for the assessment of telemedicine and a plan for testing of the model within five specialties. Helsinki: FinOHTA 1997;29.
Ohinmaa A, Hailey, D & Roine, D. The INAHTA Project on Telemedicine: The assessment of telemedicine: General principles and a systematic review. August 1999:55.
Oka A, Harima Y, Nakano Y, et al Interhospital network system using the worldwide web and the common gateway interface Journal of Digital Imaging 1999 12(2 Suppl 1):205 7 10342215
Olsson S, Busch C A national telepathology trial in Sweden feasibility and assessment Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):234 41 8526558
Ong K, Chia P, Ng WL, et al A telemedicine system for high-quality transmission of paper electrocardiographic reports Journal of Telemedicine & Telecare 1995 1(1):27 33 9375116
Otto C, Pipe A Remote, mobile telemedicine: the satellite transmission of medical data from Mount Logan Journal of Telemedicine & Telecare 1997 3(Suppl 1):84 5 9218396
Pacht ER, Turner JW, Gailiun M, et al Effectiveness of telemedicine in the outpatient pulmonary clinic Telemedicine J 1998 4(4):287 92
Pal B, Laing H, Estrach C A cyberclinic in rheumatology Journal of the Royal College of Physicians of London 1999 33(2):161 2 10340266
Pan CX, Glynn RJ, Mogun H, et al Definition of race and ethnicity in older people in Medicare and Medicaid Journal of the American Geriatrics Society 1999 47(6):730 3 10366176
Papakostopoulos D Telematic electrodiagnosis Journal of Telemedicine & Telecare 1996 2(Suppl 1):30 3 9375084
Papakostopoulos D, Everingham M, Gogolitsyn Y, et al Comprehensive standardized ophthalmic telemedicine Journal of Telemedicine & Telecare 1997 3(Suppl 1):49 52 9218382
Parchman ML, Culler SD Preventable hospitalizations in primary care shortage areas. An analysis of vulnerable Medicare beneficiaries [see comments] Archives of Family Medicine 1999 8(6):487 91> 10575386
Patel UH, Babbs CF A computer-based, automated, telephonic system to monitor patient progress in the home setting Journal of Medical Systems 1992 16(2-3):101 12 1402436
Patel T. A cost-benefit analysis of the effect of shipboard telemedicine in a selected oceanic region. Telemedicine Journal 1999.
Patients with renal disease have nephrologists online Telemedicine & Virtual Reality 1997 2(5).
Patterson S, Botchway C Dental screenings using telehealth technology: a pilot study Journal/Canadian Dental Association Journal de l Association Dentaire Canadienne 1998 64(11):806 10
Pavan-Nickoloff A, Sherrington L Link for kids: the Telehealth Project Canadian Nurse 1998 94(8):37 9 9923217
Pavlicek W, Zavalkovskiy B, Eversman WG Performance and function of a high-speed multiple star topology image management system at Mayo Clinic Scottsdale Journal of Digital Imaging 1999 12(2 Suppl 1):168 74 10342202
Pazart L, Blondel B, Breart G, et al. Evaluation of antenatal surveillance by foetal telemonitoring [abstract]. Abstracts/Annual Meeting, International Society of Technology Assessment in Health Care. ;9.
Pedersen S, Hartviksen G, Haga D Teleconsultation of patients with otorhinolaryngologic conditions: a telendoscopic pilot study Archives of Otolaryngology Head & Neck Surgery 1994 120(2):133 6 8297568
Pedersen S, Holand U Tele-endoscopic otorhinolaryngological examination: preliminary study of patient satisfaction Telemedicine Journal 1995 1(1):47 52 10165322
Pedersen S. Commentary. Journal of Telemedicine and Telecare. 1997;3:222-3.
Penrod JD, Kane RL, Finch MD, et al Effects of post-hospital Medicare home health and informal care on patient functional status Health Services Research 1998 33(3 Pt 1):513 29 9685120 1070274
Pepino A, Bracale M. A teleconsultation system for remote control of cardiac pacemakers. In: Toward an electronic patient record '97: proceedings. 1997;1997:26-7.
Perednia D, Allen A. Telemedicine technology and clinical applications. Journal of the American Medical Association. 1995;273:483-8. [pmid: 7837367].
Perednia DA, Brown NA Teledermatology: one application of telemedicine Bulletin of the Medical Library Association 1995 83(1):42 7 225996 7703938
Perednia DA Telemedicine system evaluation and a collaborative model for multi- centered research Journal of Medical Systems 1995 19(3):287 94 7643025
Perednia DA Focus. Telemedicine system evaluation, transaction models, and multicentered research Journal of the American Health Information Management Association 1996 67(1):60 5 10154050
Perednia DA, Wallace J, Morrisey M, et al The effect of a teledermatology program on rural referral patterns to dermatologists and the management of skin disease Medinfo 1998 9(Pt 1):290 3 10384464
Pettersson H, Holmer NG Teleradiology in southern Sweden-a tool for reorganization of health care and for education Computer Methods & Programs in Biomedicine 1998 57(1-2):13 9 9803993
Philbin EF, DiSalvo TG Prediction of hospital readmission for heart failure: development of a simple risk score based on administrative data Journal of the American College of Cardiology 1999 33(6):1560 6 10334424
Phillips DF Physicians put promise of telemedicine to the test: reports from rural practitioners, anesthesiologists JAMA 1996 276(4):267 8 8656525
Phillips CM, Burke WA, Allen MH, et al Reliability of telemedicine in evaluating skin tumors Telemedicine J 1998 4(1):5 9
Pickard JA Instrumentation available for remote diagnosis and consultation in eye care International Journal of Circumpolar Health 1998 57(Suppl 1):694 6 10093371
Pisanelli DM, Ricci FL, Maceratini R A survey of telemedicine in Italy Journal of Telemedicine & Telecare 1995 1(3):125 30 9375132
Platt S, Furman S, Gross JN, et al Transtelephone monitoring for pacemaker follow-up 1981-1994 Pacing & Clinical Electrophysiology 1996 19(12 part 1):2089 98 8994948
Png MA, Kaw GJ, Tan KP, et al Remote consultation for computerized tomography and magnetic resonance studies by means of teleradiology-experience at the Singapore General Hospital Journal of Telemedicine & Telecare 1997 3(Suppl 1):54 5 9218384
Potosky AL, Breen N, Graubard BI, et al The association between health care coverage and the use of cancer screening tests. Results from the 1992 National Health Interview Survey Medical Care 1998 36(3):257 70 9520952
Potter M, Zdyb T, Smith S, et al Use of advanced analytical techniques in assessing telemedicine Seminars in Perioperative Nursing 1997 6(2):121 32 9220911
Portable blood glucose monitors Health Devices 1992 21(2):41 78 1544819
Pregnant women on Britain's Isle of Wight treated through teleobstetric system Telemedicine & Virtual Reality 1997 2(5):49 50 10167775
Preston J, Brown FW, Hartley B Using telemedicine to improve health care in distant areas Hospital & Community Psychiatry 1992 43(1):25 32 1544643
Preston J Texas Telemedicine Project: a viability study Telemedicine Journal 1995 1(2):125 32 10165331
Pronovost P, Angus DC Using large-scale databases to measure outcomes in critical care Critical Care Clinics 1999 15(3):615 31, vii-viii 10442267
Providers AoTS. 1998 Report on U. S. Telemedicine Activity. Portland (OR); 1998.
Pysher L, Harlow C Teleradiology using low-cost consumer-oriented computer hardware and software American Journal of Roentgenology 1999 172(5):1181 4 10227485
Quebec CdEdTdlSd. Telehealth and telemedicine in Quebec: Current issues. Montreal: CETS; 1999. Report No.: CETS 98-7 RE.
Raab SS, Robinson RA, Snider TE, et al Telepathologic review: utility, diagnostic accuracy, and interobserver variability on a difficult case consultation service Modern Pathology 1997 10(6):630 5 9195582
Radiation-exposure victims in Russia get help via telemedicine Telemedicine & Virtual Reality 1998 3(5):
Rafuse J University of Alberta program links northern hepatitis patients with southern consultants Cmaj 1994 151(5):654 5 8069813 1337204
Ranucci D Telemedicine and Telehealth: the situation in Italy and the perspectives in Europe Rays 1991 16(4):419 26 1788407
Reddy S, Niewiadomska-Bugaj M, Reddy YV, et al. Experiences with ARTEMIS-an Internet-based telemedicine system. Proceedings/AMIA Annual Fall Symposium. 1997:759-63.
Reid DS, Weaver LE, Sargeant JM, et al Telemedicine in Nova Scotia: report of a pilot study Telemedicine J 1998 4(3):249 58
Remote radiology viewing speeds report time, reduces transfers and hospitalizations Health Care Cost Reengineering Report 1998 3(9):132 4 10185342
Rendina MC, Long WA, deBliek R Effect size and experimental power analysis in a paediatric cardiology telemedicine system Journal of Telemedicine & Telecare 1997 3(Suppl 1):56 7 9218385
Rendina MC, Downs SM, Carasco N, et al Effect of telemedicine on health outcomes in 87 infants requiring neonatal intensive care Telemedicine J 1998 4(4):345 51
Rendina MC. The effect of telemedicine on neonatal intensive care unit length of stay in very low birthweight infants. Proceedings/AMIA Annual Symposium. 1998:111-5.
Rennert WP, Hayes WS, Hauser GJ, et al The role of telemedicine in triage decisions for pediatric emergency patients Virginia Medical Quarterly 1996 123(3):171 2 8752957
Ricci MA, Callas PW, Montgomery WL The Vermont Telemedicine Project: initial implementation phases Telemedicine Journal 1997 3(3):197 205 10174344
Ricci MA, Knight SJ, Nutter B, et al Desktop telemedicine in vascular surgery: some preliminary findings Telemedicine J 1998 4(4):279 85
Richardson M Global telemedicine network to be based at Texas Medical Center Texas Medicine 1993 89(12):20 1
Richardson RJ, Goldberg MA, Sharif HS, et al Implementing global telemedicine: experience with 1097 cases from the Middle East to the USA Journal of Telemedicine & Telecare 1996 2(Suppl 1):79 82 9375101
Richter HA, Danaei M, Maurin N, et al Multimedic system for telepathology and interdisciplinary councils between doctors and various hospitals Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):296 9 8526572
Ricke J, Kleinholz L, Hosten N, et al Telemedicine in rural areas. Experience with medical desktop-conferencing via satellite Journal of Telemedicine & Telecare 1995 1(4):224 8 9375147
Ricke J, Kleinholz L, Hosten N, et al Teleradiology: use of multimedia PC for access to electronic patient records and teleconsultation Rofo Fortschritte auf dem Gebiete der Rontgenstrahlen und der Neuen Bildgebenden Verfahren 1996 165(2):188 91
Rinde E, Nordrum I, Nymo BJ Telemedicine in rural Norway World Health Forum 1993 14(1):71 7 8439382
Ripich S, Moore SM, Brennan PF A new nursing medium: computer networks for group intervention Journal of Psychosocial Nursing & Mental Health Services 1992 30(7):15 20 1494997
Rissam HS, Kishore S, Srivastava S, et al Evaluation of cardiac symptoms by trans-telephonic electro-cardiographic monitoring (TTEM): preliminary experience Indian Heart Journal 1998 50(1):55 8 9583288
Rissam HS, Kishore S, Bhatia ML, et al. Trans-telephonic electro-cardiographic monitoring (TTEM)-first Indian experience. Studies in Health Technology & Informatics. 1998;50:361-3. [pmid: 10180571].
Ritchie JL, Maynard C, Every NR, et al Coronary artery stent outcomes in a Medicare population: Less emergency bypass surgery and lower mortality rates in patients with stents American Heart Journal 1999 138(3 Pt 1):437 40 10467192
Ritchie JL, Maynard C, Every NR, et al Coronary artery stent outcomes in a Medicare population: less emergency bypass surgery and lower mortality rates in patients with stents American Heart Journal 1999 138(3 Pt 1):437 40 10467192
Rizzo N, Fulvio S, Camerucci S, et al Telemedicine for airline passengers, seafarers and islanders Journal of Telemedicine & Telecare 1997 3(Suppl 1):7 9 9218366
Robb N Telemedicine may help change the face of medical care in Eastern Canada Canadian Medical Association Journal 1997 156(7):1009 13 9099171 1227117
Robb N Children's TeleHealth Network links 3 provinces Cmaj 1997 156(7):1012 3 9138830 1227118
Robie DK, Naulty CM, Parry RL, et al Early experience using telemedicine for neonatal surgical consultations Journal of Pediatric Surgery 1172 33(7):1172 7 9694117
Roca OF, Pitti S, Cardama AD, et al Factors influencing distant tele-evaluation in cytology, pathology, conventional radiology and mammography Analytical Cellular Pathology 1996 10(1):13 23 8789266
Rodriguez MJ, Arredondo MT, del Pozo F, et al A home telecare management system Journal of Telemedicine & Telecare 1995 1(2):86 94 9375125
Roglieri JL, Futterman R, McDonough KL, et al Disease management interventions to improve outcomes in congestive heart failure American Journal of Managed Care 1997 3(12):1831 9 10178473
Rollert MK, Strauss RA, Abubaker AO, et al Telemedicine consultations in oral and maxillofacial surgery Journal of Oral & Maxillofacial Surgery 1999 57(2):136 8 9973120
Rosen MJ Telerehabilitation Neurorehabilitation 1999 12(1):11 26
Rosengren D, Blackwell N, Kelly G, et al The use of telemedicine to treat ophthalmological emergencies in rural Australia Journal of Telemedicine & Telecare 1998 4(Suppl 1):97 9 9640754
Rosenthal BE. Telemedicine Sourcebook 1998: A resource guide for the practical application of telemedicine in the managed care marketplace. New York: Faulkner & Gray, Inc.; 1997.
Roth A, Carthy Z, Benedek M Telemedicine in emergency home care-the 'Shahal' experience Journal of Telemedicine & Telecare 1997 3(Suppl 1):58 60 9218386
Rovetta A, Falcone F, Sala R, et al. Telehealth in Africa. Studies in Health Technology & Informatics. 1997;39:277-85. [pmid: 10168922].
Rubin DN, Thomas JD Telemedicine in cardiology ACC Current Journal Review 1998 7(6):93 5
Ruckauer KD, Nord M, Marescaux J, et al. Telesurgery: standards-consultations-continuing education. Langenbecks Archiv fur Chirurgie - Supplement - Kongressband. 1997;114:644-6.
Rudinsky B, Stavrovska O, Moravcikova M Telemedicine in neurosurgery Lek Tech 1999 30(3):62 4
Rural Montana uses telepsychiatry network Telemedicine & Virtual Reality 1998 3(3):
Rural Oregon gains access to dermatology specialists through telemed project. Report on Healthcare Information Management 1997.
Samedov RN An Internet station for telemedicine in the Azerbaijan Republic Journal of Telemedicine & Telecare 1998 4(Suppl 1):42 3 9640731
Sandberg L Northern California rates a "TENN" (Telemedical Emergency Neurosurgical Network) Health Management Technology 1996 17(7):17 8 10158427
Sandberg L, Chodroff P TENN rates an 11: Northern California telemedicine project saves $500,000 Health Management Technology 1998 19(1):29 30 10177933
Scerri GV, Vassallo DJ Initial plastic surgery experience with the first telemedicine links for the British Forces British Journal of Plastic Surgery 1999 52(4):294 8 10624297
Schall LC, Marsh GM, Henderson VL A two-stage protocol for verifying vital status in large historical cohort studies Journal of Occupational & Environmental Medicine 1997 39(11):1097 102 9383720
Schanz SJ Proposed HCFA regulations offer telemedicine opportunities Telemedicine Today 1998 6(4).
Schiller AE, Jr, Bondmass M, Avitall B Technology-based home care for disease management Remington Report 1997 5(5):10 2
Scholz TD, Kienzle MG Optimizing utilization of pediatric echocardiography and implications for telemedicine American Journal of Cardiology 1999 83(12):1645 8 10392869
Schuckman P AmeriCares links urban Conn. clinic for indigent to doctors, hospital Healthcare Systems Strategy Report 1995 12(21):5 6 10152392
Schulam PG, Docimo SG, Saleh W, et al Telesurgical mentoring. Initial clinical experience Surgical Endoscopy 1997 11(10):1001 5 9381336
Sclafani AP, Heneghan C, Ginsburg J, et al Teleconsultation in otolaryngology: live versus store and forward consultations Otolaryngology & Head & Neck Surgery 1999 120(1):62 72
Screnci D, Hirsch E, Levy K, et al Medical outreach to Armenia by telemedicine linkage Journal of Medical Systems 1996 20(2):67 76 8798949
Sederer L, Dickey B. Outcomes Assessment in Clinical Practice. Baltimore, MD: Williams and Wilkins; 1996.
Sederer L, Dickey B, e. Outcomes Assessment in Clinical Practice. Baltimore MD: Williams and Wilkins; 1996.
Sepulveda W, Drysdale K, Kyle PM, et al Remote fetal medicine consultation using stored ultrasound video images Journal of Telemedicine & Telecare 1995 1(2):117 9 9375129
Sezeur A Surgical applications of telemedicine Annales de Chirurgie 1998 52(5):403 11 9752478
Sezeur A, de Gramont A, Touboul E, et al Contribution of telemedicine applied to digestive cancer Gastroenterologie Clinique et Biologique 1999 23(3):342 7 10384336
Shalabudin DSH Electronic CME, health education and telemedicine in Malaysia Educ Health 1998 11(3):411 2
Shalala D. DHHS Secretary cover letter to the Vice President. In: 1997.
Shanit D, Cheng A, Greenbaum RA Telecardiology: supporting the decision-making process in general practice Journal of Telemedicine & Telecare 1996 2(1):7 13 9375036
Shanit D The Israel Center of Telemedicine. Telecardiology in the Negev Telemedicine Today 1996 4(4):43 4 10165141
Shanit D, Greenbaum RA Towards a comprehensive telecardiology monitoring centre for community-based services Journal of Telemedicine & Telecare 1997 3(Suppl 1):60 2 9218387
Shanit D, Lifshitz T, Giladi R, et al A pilot study of tele-ophthalmology outreach services to primary care Journal of Telemedicine & Telecare 1998 4(Suppl 1):1 2 9640715
Shaw DK, Sparks KE, Jennings HS, 3rd, et al Cardiac rehabilitation using simultaneous voice and electrocardiographic transtelephonic monitoring American Journal of Cardiology 1995 76(14):1069 71 7484865
Shea D, Stuart B, Vasey J, et al Medicare physician referral patterns Health Services Research 1999 34(1 Pt 2):331 48 10199679 1089005
Sheikh K, Bullock C Urban-rural differences in Medicare in Missouri Missouri Medicine 1999 96(2):67 73 10036916
Sheng OR, Hu PJ, Au G, et al Urban teleradiology in Hong Kong Journal of Telemedicine & Telecare 1997 3(2):71 7 9206276
Shepherd B Establishing radiologic image transmission via a transmission control protocol/Internet protocol network between two teaching hospitals in Houston Journal of Digital Imaging 1999 12(2 Suppl 1):88 90 10342176
Shepperd S, Harwood D, Jenkinson C, et al Randomised controlled trial comparing hospital at home care with inpatient hospital care. I: three month follow up of health outcomes Bmj 1998 316(7147):1786 91 28578 9624068
Shepperd S, Iliffe S The effectiveness of hospital at home compared with in-patient hospital care: a systematic review. [Review] [20 refs] Journal of Public Health Medicine 1998 20(3):344 50 9793901
Shepperd S, Harwood D, Gray A, et al Randomised controlled trial comparing hospital at home care with inpatient hospital care. II: cost minimisation analysis Bmj 1998 316(7147):1791 6 28579 9624069
Shimada M, Akaishi M, Asakura K, et al Usefulness of the newly developed transtelephonic electrocardiogram and computer-supported response system Journal of Cardiology 1996 27(4):211 7 8642508
Shimosato Y, Yagi Y, Yamagishi K, et al Experience and present status of telepathology in the National Cancer Center Hospital, Tokyo Zentralblatt fur Pathologie 1992 138(6):413 7 1297434
Shindoh M, Nishi S, Kurita S, et al Tele-ECG transmission for patients with out-of-hospital cardiac arrest in Osaka City Masui - Japanese Journal of Anesthesiology 1995 44(6):890 4
Shtern F Mobile Breast Care Center: a joint program of the Department of Defense, U.S. Public Health Service's Office on Women's Health, and the National Cancer Institute Academic Radiology 1998 5(Suppl 2):S409 10 9750869
Shultz EK, Bauman A, Hayward M, et al. Improved care of patients with diabetes through telecommunications. Annals of the New York Academy of Sciences. 1992;670:141-5. [pmid: 1309083].
Siderfin CD Low-technology telemedicine in Antarctica Journal of Telemedicine & Telecare 1995 1(1):54 60 9375120
Siderfin CD, Haston W, Milne AH Telemedicine in the British Antarctic Survey Medical Unit Journal of Telemedicine & Telecare 1995 1(2):63 8 9375122
Silverman EM, Skinner JS, Fisher ES The association between for-profit hospital ownership and increased Medicare spending New England Journal of Medicine 1999 341(6):420 6 10432327
Sjogren LH, Hessfelt M, Olsson S. Regional telemedicine in the South part of Sweden [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. ;13.
Slipy SM Boston hospital using seven telemedicine systems within facility Health Management Technology 1995 16(12):
Slipy SM Telemedicine and interconnection services reduce costs at several facilities. Prison and health system partner with Ameritech Health Management Technology 1995 16(8).
Smith DL Technology. Teleassessment: a model for team developmental assessment of high-risk infants using a televideo network Infants & Young Children 1997 9(4):58 61
Smyth KA, Harris PB Using telecomputing to provide information and support to caregivers of persons with dementia Gerontologist 1993 33(1):123 7 8440495
Snow C Mobile telemedicine clinic eases care in Oklahoma Modern Healthcare 1996 26(32):
Sobczyk WL, Solinger RE, Rees AH, et al Transtelephonic echocardiography: successful use in a tertiary pediatric referral center Journal of Pediatrics 1993 122(6):S84 8 8501554
Sohn C, Beldermann F, Wallwiener D, et al Telecommunication - a possibility to improve prenatal and gynecological ultrasound diagnosis - preliminary results Zentralblatt fur Gynakologie 1997 119(4):177 80 9206924
Sparks KE, Shaw DK, Eddy D, et al Alternatives for cardiac rehabilitation patients unable to return to a hospital-based program Heart & Lung 1993 22(4):298 303 8360063
Square D Fetal alcohol syndrome diagnosed by telelink in Manitoba Cmaj 1999 160(5):
Srikanthan VS, Pell AC, Prasad N, et al Use of fax facility improves decision making regarding thrombolysis in acute myocardial infarction Heart 1997 78(2):198 200 9326998 484904
Steffen B, Gianom D, Winkler C, et al Frozen section diagnosis using telepathology Swiss Surgery 1997 3(1):25 9 9064125
Stern J, Heneghan C, Sclafani AP, et al Telemedicine applications in otolaryngology Journal of Telemedicine & Telecare 1998 4(Suppl 1):74 5 9640745
Stevens A, Milne R, Lilford RJ, et al. How do new technologies get into practice? Keeping pace with new technologies: systems needed to identify and evaluate them. Bmj. 1999;319:1291-5. [pmid: 10559044]. [pmcid: 1129069].
Stieglitz SP, Gnann W, Schachinger U, et al Telecommunication in trauma surgery. Communication networks of hospitals in East Bavaria Chirurg 1998 69(11):1123 8 9864615
Stoeger A, Strohmayr W, Giacomuzzi SM, et al A cost analysis of an emergency computerized tomography teleradiology system Journal of Telemedicine & Telecare 1997 3(1):35 9 9139759
Stoger A, Giacomuzzi SM, Strohmayr W, et al Establishment of an emergency CT service by means of teleradiology Rofo Fortschritte auf dem Gebiete der Rontgenstrahlen und der Neuen Bildgebenden Verfahren 1996 165(6):520 3
Stoloff PH, Garcia FE, Thomason JE, et al A cost-effectiveness analysis of shipboard telemedicine Telemedicine J 1998 4(4):293 304
Strange-Vognsen HH, Knudstorp N Radio medical advice-the Danish experience Journal of the Royal Naval Medical Service 1995 81(1):12 5 7562700
Suhonen R Teledermatology trial in Finland [letter] Journal of Telemedicine & Telecare 1997 3(1):61 2 9139764
Suleiman AB, Mohan J Pacific Rim report: Malaysia Telemedicine Today 1998 6(6).
Sullivan E, Rheuban KS University of Virginia Telemedicine Program. Improving Access Virginia Medical Quarterly 1996 123(3):
Sunshine JH, Bushee GR, Mallick R U. S. radiologists' workload in 1995-1996 and trends since 1991-1992 Radiology 1998 208(1):19 24 9646788
Susman E Telemedicine permits overnight dialysis at home. Health care workers watch for problems from office Telemedicine & Virtual Reality 1997 2(2):13 4 10165828
Strategies. UC Davis unveils ER tele-monitoring project to speed intrasystem patient data retrieval. Report on Healthcare Information Management 1997.
Swedish hospitals field test telepathology Telemedicine & Virtual Reality 1998 3(1):
Swanson B. Challenging the tyranny of distance: telemedicine in Australia. In: Toward an electronic patient record '97: proceedings. 1997;1997:244-7.
Swett HA, Holaday L, Leffell D, et al Telemedicine: delivering medical expertise across the state and around the world Connecticut Medicine 1995 59(10):593 602 7587175
Tachakra S, Sivakumar A, Everard R, et al Remote trauma management-setting up a system Journal of Telemedicine & Telecare 1996 2(Suppl 1):65 8 9375096
Tachakra S, Freij R, Mullett S, et al Teleradiology or teleconsultation for emergency nurse practitioners? Journal of Telemedicine & Telecare 1996 2(Suppl 1):56 8 9375093
Tachinardi U Internet and healthcare in Brazil: the role of the working group for healthcare (GT Saude) Computers in Biology & Medicine 1998 28(5):519 29 9861509
Takizawa M, Sone S, Aoki J, et al High-resolution teleradiology system based on ISDN and small computer Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica 1995 55(1):65 9 7899067
Tampa Bay subacute hospital & telemedicine firm form joint venture to introduce new technology ASCA Quarterly 1995 3(2):1995 6
Tangalos EG Clinical trials to validate telemedicine Journal of Medical Systems 1995 19(3):281 5 7643024
Taylor P A survey of research in telemedicine. 2: telemedicine services Journal of Telemedicine & Telecare 1998 4(2):63 71 9744160
Taylor P An assessment of potential effect of a teledermatology system Journal of Telemedicine and Telecare 2000 6(Supplement 1):74 6
Teaching centers take larger role in prison care TB Monitor 1998 5(2):17 9
Technical Telehealth Standards; 1998.
Technology makes home monitoring safe Case Management Advisor 1995 6(4).
Technology ... rural hospitals' expanding their reach through telemedicine Hospitals & Health Networks 1997 71(17):25 6
Technology ... telemedicine project to monitor renal dialysis patients Hospitals & Health Networks 1997 71(8):
Teledermatology solves a nasty skin problem at the bottom of the world Telemedicine & Virtual Reality 1997 2(9):105 6
Tele-imaging enables hospital to extend its services world-wide Telemedicine Today 1998 6(2):Apr-May.
Telemed consultations teach GPs about specialties, network finds Healthcare Systems Strategy Report 1995 12(23):
Telemedicine brings high quality health care to rural Pennsylvania Pennsylvania Medicine 1994 97(10):
Telemedicine diagnosis launched at Health Waikato New Zealand Health & Hospital 1995 47(5):8 9
Telemedicine ISf. ISFT Conference '99. ? Stockholm, Sweden: International Society for Telemedicine; 1999.
Telemedicine network increases clinical access for Texas prison Clinical Data Management 1995 2(7):4 5
Telemedicine program saves health system money, offers relief to rural providers Health Care Cost Reengineering Report 1997 2(2):22 4 10175055
Telemedicine provider markets to managed care Case Management Advisor 1997 8(7):118 9
Telemedicine to play key role in combating fetal alcohol syndrome on the prairie Telemedicine & Virtual Reality 1998 3(12):133 4
Teleradiology reduces errors in suspected heart attacks Telemedicine & Virtual Reality 1998 3(2):13 4
Terreros DA, Martinez R Blueprint for multimedia telemedicine networks in the Rocky Mountain Veterans Integrated Service Network (VISN-19) Telemedicine Journal 1997 3(1):33 42 10166443
Teslow TN, Gilbert RA, Grant WH, 3rd, et al A teleradiology case conference system Journal of Telemedicine & Telecare 1995 1(2):95 9 9375126
The future of home medical device technology: separating fads from facts Home Healthcare Consultant 1998 5(1):21 4
The wired health system: telemedicine comes of age Health Care Cost Reengineering Report 1998 3(8):121 3 10182722
Tichenor J, Balch D, Gustke S, et al Operational issues at the East Carolina University School of Medicine Telemedicine Today 1996 4(2):28 9 10165536
Tilson D, Fahey C. Introduction. In: Tilson D, editor. Aging in Place: Supporting the Frail Elderly in Residential Environments. Glenview, IL: Scott, Foresman and Co.; 1990. p. xv-xxxiii.
Tobis J, Aharonian V, Mansukhani P, et al Video networking of cardiac catheterization laboratories American Heart Journal 1999 137(2):241 9 9924157
Togno J, Ash A, Mitchell J Australian telemedicine. Gearing up down under Telemedicine Today 1996 4(6):42 3 10165150
Tohme WG, Olsson S. A methodological review of telemedicine: developments and directions [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 12.
Tohme WG, Winchester JF, Collmann J, et al Remote management of haemodialysis patients: design and implementation of a telemedicine network Minimally Invasive Therapy 1997 6(5-6):421 8
Tohme WG, Hayes WS, Winchester JF, et al Requirements for urology and renal dialysis PC-based telemedicine applications: comparative analysis Telemedicine Journal 1997 3(1):19 25 10166441
Tong F, Yee KC, Liew S, et al The Tele-Healthcare Information System at the Chinese University of Hong Kong [letter] Journal of Telemedicine & Telecare 1996 2(4):226 7 9375064
Trippi JA, Lee KS, Kopp G, et al Emergency echocardiography telemedicine: an efficient method to provide 24-hour consultative echocardiography Journal of the American College of Cardiology 1748 27(7):1748 52 8636564
Trippi JA, Kopp G, Lee KS, et al The feasibility of dobutamine stress echocardiography in the emergency department with telemedicine interpretation Journal of the American Society of Echocardiography 1996 9(2):113 8 8849606
Trippi JA, Lee KS, Kopp G, et al Dobutamine stress tele-echocardiography for evaluation of emergency department patients with chest pain Journal of the American College of Cardiology 1997 30(3):627 32 9283518
Trott P The Queensland Northern Regional Health Authority telemental health project Journal of Telemedicine & Telecare 1996 2(Suppl 1):98 104 9375108
Trott P, Blignault I Cost evaluation of a telepsychiatry service in northern Queensland Journal of Telemedicine & Telecare 1998 4(Suppl 1):66 8 9640742
Tsagaris M, Chatzipantazi P, Tsarouhi A, et al Outpatient teleclinics: six months' experience at the Telemedicine Centre, Sismanoglion Hospital of Athens Journal of Telemedicine & Telecare 1996 2(Suppl 1):106 7 9375110
Tsagaris MJ, Papavassiliou MV, Chatzipantazi PD, et al The contribution of telemedicine to cardiology Journal of Telemedicine & Telecare 1997 3(Suppl 1):63 4 9218388
Tsibulkin EK, Goldberg SI, Makhanek AO, et al Creating a computer-aided intellectual environment for a consultative center of intensive care Medinfo 1995 8(Pt 1):
Tsuchiya H Telemedicine using a desktop conference system (Phoenix) in Kyushu, Japan Telemedicine J 1998 4(1):43 8
Udvarhelyi IS, Colditz GA, Rai A, et al Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly? Annals of Internal Medicine 1992 116(3):238 44 1530808
Ueno T, Yamaguchi T A home-care type telemedicine setup using ISDN and TV conference system Japanese Journal of Medical Electronics & Biological Engineering 1998 36(3):215 7
Uldal SB, Stormer J, Sund T Considerations on time and use: teleradiology experiences from northern Norway Telemedicine Today 1997 5(5):26 7 10174339
Uldal SB, Sund T, Stormer J Four years with teleradiology: a technical description Telemedicine Journal 1997 3(3):235 41 10174348
Up-and-comers: programs demonstrate top potential Telemedicine & Telehealth Networks 1996 2(11).
Urban V, Busert C, Huwel N, et al Teleconsultation: a new neurosurgical image transfer system for daily routine and emergency cases-a four-year study European Journal of Emergency Medicine 1996 3(1):5 8 8886663
Urology operations linked to four sites Telemedicine & Virtual Reality 1998 3(9).
VA hospitals in New York State link up in telemedicine network Telemedicine & Virtual Reality 1997 2(1).
Vassallo DJ, Buxton PJ, Kilbey JH, et al The first telemedicine link for the British Forces Journal of the Royal Army Medical Corps 1998 144(3):125 30 9819718
Vaughan BJ, Torok KE, Kelly LM, et al. A client/server approach to telemedicine. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:776-80.
Video phones add new twist to home care Hospital Peer Review 1997 22(4):49 50 10166113
Vidmar DA The history of teledermatology in the Department of Defense Dermatologic Clinics 1999 17(1):113 24, ix 9986999
Viirre E. Vestibular telemedicine and rehabilitation. Applications for virtual reality. Studies in Health Technology & Informatics. 1996;29:299-305. [pmid: 10163763].
Viirre E, Warner D, Balch D, et al Remote medical consultation for vestibular disorders: technological solutions and case report Telemedicine Journal 1997 3(1):53 8 10166445
Viitanen J, Sund T, Rinde E, et al Nordic teleradiology development Computer Methods & Programs in Biomedicine 1992 37(4):273 7 1395528
Vincent JA, Cavitt DL, Karpawich PP Diagnostic and cost effectiveness of telemonitoring the pediatric pacemaker patient Pediatric Cardiology 1997 18(2):86 90 9049117
Vitale MG, Krant JJ, Gelijns AC, et al Geographic variations in the rates of operative procedures involving the shoulder, including total shoulder replacement, humeral head replacement, and rotator cuff repair Journal of Bone & Joint Surgery - American Volume 1999 81(6):763 72
Vorland LH Good experiences with telemedicine in the regional hospital of Tromso Nordisk Medicin 1992 107(10):241 3 1408718
Vujovic M, Vujovic I, Kuzmanic I New technologies in diagnosing occupational asbestosis Arhiv Za Higijenu Rada i Toksikologiju 1998 49(3):251 8 10376357
Wachter G, Brown N, Allen A Teleradiology service providers Telemedicine Today 1996 4(6):14 5 10165147
Wagner G Memo from the future: telemedicine in Iowa Healthcare Information Management 1995 9(3):3 11 10152304
Wagstaff A. QALY's and the equity-efficiency trade-off. Journal of Health Economics. 1991;10:21-41. [pmid: 10113661].
Walker L Video teleconferencing: saving lives & costs in Texas Healthcare Informatics 1992 9(11):30 2 10122394
Wallace S, Wyatt J, Taylor P Telemedicine in the NHS for the millennium and beyond Postgraduate Medical Journal 1998 74(878):721 8 10320886
Walters TJ Deployment telemedicine: the Walter Reed Army Medical Center experience Military Medicine 1996 161(9):531 6 8840793
Wasson JH, Bubolz TA, Lynn J, et al Can we afford comprehensive, supportive care for the very old? Journal of the American Geriatrics Society 1998 46(7):829 32 9670868
Watanabe M Telehealth in Canada [editorial] Telemedicine Journal 1998 4(3):197 8 9882149
Watson DS Telemedicine Medical Journal of Australia 1989 151(2):62 71 2739609
Watson D Teaching over the telephone: where telecommunications and medicine meet British Journal of Healthcare Computing & Information Management 1996 13(10):24 5
Watts LA, Monk AF Telemedicine: what happens in remote consultation International Journal of Technology Assessment in Health Care 1999 15(1):220 35 10407608
Watts LA, Monk AF Telemedicine. What happens in remote consultation International Journal of Technology Assessment in Health Care 1999 15(1):220 35 10407608
Weinberg DS How is telepathology being used to improve patient care? Clinical Chemistry 1996 42(5):831 5 8653924
Weinberg DS, Allaert FA, Dusserre P, et al Telepathology diagnosis by means of digital still images: an international validation study Human Pathology 1996 27(2):111 8 8617451
Weinstein RS, Bhattacharyya A, Yu YP, et al Pathology consultation services via the Arizona-International Telemedicine Network Archives d Anatomie et de Cytologie Pathologiques 1995 43(4):219 26 8526556
Weinstein MH, Epstein JI Telepathology diagnosis of prostrate needle biopsies Human Pathology 1997 28(1):22 9 9013827
Welz R, Ligier Y, Ratib O Design of a cooperative teleradiology system Telemedicine Journal 1995 1(3):195 201 10165156
Werner A, Anderson LE Rural telepsychiatry is economically unsupportable: the Concorde crashes in a cornfield Psychiatric Services 1998 49(10):1287 90 9779895
Wheeler T Corrections-based telemedicine programs top most-active list Telemedicine Today 1998 6(3):38 9
Wheeler T Telemedicine and special needs children Telemedicine Today 1998 6(4):16 20 10182371
Wheeler T Urban kids receive telemedical care at school Telemedicine Today 1998 6(2):
Wheeler T West Texas community gets school-based telemedicine clinic Telemedicine Today 1998 6(3).
Whited JD, Mills BJ, Hall RP, et al A pilot trial of digital imaging in skin cancer Journal of Telemedicine & Telecare 1998 4(2):108 12 9744167
Whited JD, Hall RP, Simel DL, et al Reliability and accuracy of dermatologists' clinic-based and digital image consultations Journal of the American Academy of Dermatology 1999 41(5 Pt 1):693 702 10534630
Whiting R TARDIS - An intensive care telemedicine project International Journal of Clinical Monitoring & Computing 1997 14(2):123 4
Whiting R, Hayes L The practice of telemedicine - the TARDIS perspective Informatics in Healthcare Australia 1997 6(3):103 6
Whittemore KR, Afrin J. A cost/benefit analysis of a state-wide application of telemedicine technology to provide psychiatric services to a population with special needs [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care ;12:18.
Whitten P, Mair F, Collins B Home telenursing in Kansas: patients' perceptions of uses and benefits Journal of Telemedicine & Telecare 1997 3(Suppl 1):67 9 9218390
Whitten P, Collins B Nurse reactions to a prototype home telemedicine system Journal of Telemedicine & Telecare 1998 4(Suppl 1):50 2 9640735
Whitten P, Cook DJ, Shaw P, et al Telekid Care: bringing health care into schools Telemedicine Journal 1998 4(4):335 43 10220474
Williams BH, Mullick FG, Becker RL, et al A national treasure goes online: the Armed Forces Institute of Pathology MD Computing 1998 15(4):260 5 9673094
Williamson TH, Keating D Telemedicine and computers in diabetic retinopathy screening British Journal of Ophthalmology 1998 82(1):5 6 9536870 1722342
Wilson JL, Branigan A Location of East Carolina University School of Medicine telemedicine sites in relation to primary care health professional shortage areas for North Carolina's health service area VI, 1997 Journal of Public Health Management & Practice 1999 5(2):45 6 10537821
Winchester JF, Tohme WG, Schulman KA, et al Hemodialysis patient management by telemedicine: design and implementation ASAIO Journal 1997 43(5):M763 M6 9360149
Winter WC, Goodgold K, Hellige M, et al. Evaluation of telehome nursing management of congestive heart failure. In: HIMSS '98 Imagine the future: proceedings of the 1998;1998:211-9.
Wirthlin DJ, Buradagunta S, Edwards RA, et al Telemedicine in vascular surgery: feasibility of digital imaging for remote management of wounds Journal of Vascular Surgery 1998 27(6):1089 100 9652471
Woods K, Kutlar A, Grigsby RK, et al Primary-care delivery for sickle cell patients in rural Georgia using telemedicine Telemedicine Journal 1998 4(4):353 61 10220476
Wootton R Telemedicine: a cautious welcome Bmj 1996 313(7069):1375 7 8956707
Wootton R, Dornan J, Fisk NM, et al The effect of transmission bandwidth on diagnostic accuracy in remote fetal ultrasound scanning Journal of Telemedicine & Telecare 1997 3(4):209 14 9614736
Wootton R Telemedicine: the current state of the art Minimally Invasive Therapy 1997 6(5-6):393 403
Wootton R, Loane M, Mair F, et al A joint US-UK study of home telenursing Journal of Telemedicine & Telecare 1998 4(Suppl 1):83 5 9640748
Wootton R Telemedicine in the National Health Service Journal of the Royal Society of Medicine 1998 91(12):614 21 10730107 1296978
Wootton R, Barry-Kinsella C, Dornan J. Experience with a transnational fetal ultrasound link between Belfast and Dublin. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 8.
Wootton R, Bloomer SE, Corbett R, et al. Multicentre randomised control trial comparing real time teledermatology with conventional outpatient dermatological care: societal cost-benefit analysis. British Medical Journal. 2000;320:1252-6. [pmcid: 27370]. [pmid: 10797038].
Worth ER, Patrick TB, Klimczak JC, et al. Cost-effective clinical uses of wide-area networks: electronic mail as telemedicine. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:814-8.
Wu J, Kessler DK, Chakko S, et al A cost-effectiveness strategy for transtelephonic arrhythmia monitoring American Journal of Cardiology 1995 75(2):184 5 7810501
Wu TK, Liu JL, Tschai HJ, et al An ISDN-based telemedicine system Journal of Digital Imaging 1998 11(3 Suppl 1):93 5 9735442
Wynn-Jones J, Lewis L, Groves-Phillips S Telemedicine: if it is the answer, then what are the questions? British Journal of Hospital Medicine 1996 55(1-2):4 5 8646391
Yamamoto LG Wireless teleradiology and fax using cellular phones and notebook PCs for instant access to consultants American Journal of Emergency Medicine 1995 13(2):184 7 7893306
Yamamoto LG, Ash KM, Boychuk RB, et al Personal computer teleradiology interhospital image transmission of neonatal radiographs to facilitate tertiary neonatology telephone consultation and patient transfer Journal of Perinatology 1996 16(4):292 8 8866301
Yawn B, Krein S, Christianson J, et al Rural radiology: who is producing images and who is reading them? Journal of Rural Health 1997 13(2):136 44 10169320
Yellowlees P, McCoy WT Telemedicine - a health care system to help Australians Medical Journal of Australia 1993 159(7):437 8 8412912
Yellowlees P, Kennedy C Telemedicine applications in an integrated mental health service based at a teaching hospital Journal of Telemedicine & Telecare 1996 2(4):205 9 9375060
Yellowlees P The use of telemedicine to perform psychiatric assessments under the Mental Health Act Journal of Telemedicine & Telecare 1997 3(4):224 6 9614738
Yogesan K, Constable IJ, Eikelboom RH, et al Tele-ophthalmic screening using digital imaging devices Australian & New Zealand Journal of Ophthalmology 1998 26(Suppl 1):S9 11 9685010
Yoo SK, Kim SH, Kim NH, et al Design of an emergency teleradiology system based on progressive transmission Yonsei Medical Journal 1995 36(5):426 37 8546001
Young RF Telemedicine's role in domestic catastrophic disaster preparedness and response Journal of Medical Systems 1995 19(2):175 87 7602250
Zahlmann G, Walther HD, Liesenfeld B, et al Teleconsultation network for ophthalmology-experiences and results Klinische Monatsblatter fur Augenheilkunde 1998 212(2):111 5 9577811
Zarate CA, Jr., Weinstock L, Cukor P, et al Applicability of telemedicine for assessing patients with schizophrenia: acceptance and reliability Journal of Clinical Psychiatry 1997 58(1):22 5 9055833
Zelickson BD, Homan L Teledermatology in the nursing home Archives of Dermatology 1997 133(2):171 4 9041829
Zhang Y, Bai J, Zhou X, et al First trial of home ECG and blood pressure telemonitoring system in Macau Telemedicine Journal 1997 3(1):67 72 10166447
Zimnik PR A brief survey of Department of Defense Telemedicine Telemedicine Journal 1996 2(3):241 6 10165547
Zincone LH, Jr., Doty E, Balch DC Financial analysis of telemedicine in a prison system Telemedicine Journal 1997 3(4):247 55 10176005