# References

1 Perednia D, Allen A. Telemedicine technology and clinical applications. JAMA. 1995;273:483-8. [pmid: 7837367].
2 Fleming S, HA Williamson J, Hicks L, et al Rural hospital closures and access to services Hospital Health Services Administration 1995(40):247 62
3 Pronovost P, Angus DC Using large-scale databases to measure outcomes in critical care Crit Care Clin 1999 15(3):615 31, vii-viii 10442267
4 Grigsby B, Brown N. 1998 Report on U. S. Telemedicine Activity. Portland (OR): Association of Telemedicine Service Providers; 1998.
5 Allen A, Patterson JD Annual survey: teleradiology service providers Telemed Today 1997 5(5):24 5 10174338
6 Allen A, Grigsby B 5th annual program survey-Part 2. Consultation activity in 35 specialties Telemed Today 1998 6(5):18 9 10339332
7 Millman M, ed. Access to Health Care in America. Washington, DC: National Academy Press; 1993.
8 U. S. Census Bureau; 1995.
9 Health Care in Rural America. Office of Technology Assessment 1990;Washington, DC.
10 Pearson TA, Lewis C Rural epidemiology: insights from a rural population laboratory Am J Epidemiol 1998 148(10):949 57 9829866
11 Edelman M, Menz B. Selected comparisons and implications of a national rural and urban survey on health care access, demographics and policy issues. J Rural Health. 1996;12:197-205. [pmid: 10162851].
12 Ricketts T, Slifkin R, Johnson-Webb K. Patterns of health maintenance organization service areas in rural counties. Health Care Financ Rev. 1995;17:99-113. [pmid: 10153478].
13 Lambert D, Agger M. Access of rural AFDC Medicaid beneficiaries to mental health services. Health Care Financ Rev. 1995;17:133-45. [pmid: 10153467].
14 Muus K, Ludtke R, Gibbens B. Community perceptions of rural hospital closure. J Community Health. 1995;20:65-73. [pmid: 7699110].
15 Dansky K, Dirani R. The use of health care services by people with diabetes in rural areas. J Rural Health. 1998;14:129-37. [pmid: 9715001].
16 American College of Physicians. Rural Primary Care. Ann Intern Med. 1995;122:380-90. [pmid: 7847653].
17 Kohrs FP Can market-based solutions work for all of Medicare? Barriers to reform in the Medicare population residing in health professional shortage areas South Med J 1997 90(5):493 7 9160065
18 Parchman ML, Culler SD Preventable hospitalizations in primary care shortage areas. An analysis of vulnerable Medicare beneficiaries [see comments] Arch Fam Med 1999 8(6):487 91 10575386
19 Krakauer H, Jacoby I, Millman M, et al Physician impact on hospital admission and on mortality rates in the Medicare population Health Serv Res 1996 31(2):191 211 8675439 1070113
20 Shalala D. DHHS Secretary cover letter to the President. 1997.
21 Annual Report To Congress Chapter 7: Telemedicine Services Report Prepared By The Physician Payment Review Commission. 1995.
22 Grigsby J, Kaehny MM, Sandberg EJ, et al Effects and effectiveness of telemedicine Health Care Finance Rev 1995 17(1):115 31
23 Washington, DC: National Academy Press; 1996.
24 Montreal: CETS; 1999. Report No.: CETS 98-7 RE.
25 Issues and Opportunities Facing VHA Telemedicine: Reinventing Service To Patients. In: Telemedicine Strategic Healthcare Group, 1999.
26 International Society for Telemedicine Conference 1999. Stockholm, Sweden.
27 Technical Telehealth Standards; 1998.
28 Rosenthal BE. Telemedicine Sourcebook 1998: A resource guide for the practical application of telemedicine in the managed care marketplace. New York: Faulkner & Gray, Inc.; 1997.
29 Ohinmaa A, Hailey D, Roine D. The INAHTA Project on Telemedicine: The assessment of telemedicine: General principles and a systematic review. August 1999:55.
30 Currell R, Urquhart C, Wainwright P, et al. Telemedicine versus face-to-face consultations: Effects on professional practice and health care outcomes. Oxford, United Kingdom; 2000.
31 Almazan C, Gallo P. Assesssing clinical benefit and economic evaluation in telemedicine. Barcelona: Catalan Agency for Health Technology Assessment; May, 1999.
32 Grigsby B. 2000. [pmcid: 384376].
33 Chesnut R, Carney N, Maynard H, et al. Rehabilitation for Traumatic Brain Injury. Evidence report no. 2 (Contract 290-97-0018 to Oregon Health Sciences University). Rockville, MD: Agency for Health Care Policy and Research; 1999.
34 Lijmer JG, Mol BW, Heisterkamp S, et al Empirical evidence of design-related bias in studies of diagnostic tests JAMA 1999 282(11):1061 6 10493205
35 Egglin TK, Feinstein AR Context bias. A problem in diagnostic radiology JAMA 1996 276(21):1752 5 8940325
36 Udvarhelyi IS, Colditz GA, Rai A, et al Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly? Ann Intern Med 1992 116(3):238 44 1530808
37 Gold M, Siegel J, Russell L, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
38 Report of the Interdisciplinary Telehealth Standards Group; 1998.
39 Gomez EJ, Del Pozo F, Hernando ME Telemedicine for diabetes care: The DIABTel approach towards diabetes telecare Med Inf 1996 21(4):283 95
40 Lindberg CC Implementation of in-home telemedicine in rural Kansas: Answering an elderly patient's needs J Am Med Inf Assoc 1997 4(1):14 7
41 Nitzkin JL, Zhu N, Marier RL Reliability of telemedicine examination Telemed J 1997 3(2):141 57 10168280
42 Tohme WG, Hayes WS, Winchester JF, et al Requirements for urology and renal dialysis PC-based telemedicine applications: Comparative analysis Telemed J 1997 3(1):19 25 10166441
43 Tohme WG, Winchester JF, Collmann J, et al Remote management of haemodialysis patients: Design and implementation of a telemedicine network Minim Invasive Ther 1997 6(5-6):421 8
44 Keating NL, Zaslavsky AM, Ayanian JZ Physicians' experiences and beliefs regarding informal consultation JAMA 1998 280(10):900 4 9739974
45 Kuo D, Gifford DR, Stein MD Curbside consultation practices and attitudes among primary care physicians and medical subspecialists JAMA 1998 280(10):905 9 9739975
46 Golub RM Curbside consultations and the viaduct effect [editorial; comment] JAMA 1998 280(10):929 30 9739980
47 Telephone, in-person triage of same patients often don't agree, UCLA study concludes Data Strategies Benchmarks 1999 3(6):94 5 10557779
48 Krupinski E, LeSueur B, Ellsworth L, et al Diagnostic accuracy and image quality using a digital camera for teledermatology Telemed J 1999 5(3).
49 Whited JD, Hall RP, Simel DL, et al Reliability and accuracy of dermatologists' clinic-based and digital image consultations J Am Acad Dermatol 1999 41(5 Pt 1):693 702 10534630
50 Zelickson BD, Homan L Teledermatology in the nursing home Arch Dermatol 1997 133(2):171 4 9041829
51 Kvedar JC, Edwards RA, Menn ER, et al. The substitution of digital images for dermatologic physical examination. Arch Dermatol. 1997;133:161-7. [pmid: 9041828].
52 Whited JD, Mills BJ, Hall RP, et al A pilot trial of digital imaging in skin cancer J Telemed Telecare 1998 4(2):108 12 9744167
53 Sclafani AP, Heneghan C, Ginsburg J, et al Teleconsultation in otolaryngology: Live versus store and forward consultations Otolaryngol Head Neck Surg 1999 120(1):62 72 9914551
54 Furukawa M, Furukawa MK, Mizojiri G, et al Telemedicine in laryngology Telemed J 1998 4(4):329 33 10220473
55 Houston MS, Myers JD, Levens SP, et al Clinical consultations using store-and-forward telemedicine technology Mayo Clin Proc 1999 74(8):764 9 10473351
56 Marcus DM, Brooks SE, Ulrich LD, et al Telemedicine diagnosis of eye disorders by direct ophthalmoscopy. A pilot study Ophthalmology 1998 105(10):1907 14 9787363
57 Wirthlin DJ, Buradagunta S, Edwards RA, et al Telemedicine in vascular surgery: feasibility of digital imaging for remote management of wounds J Vasc Surg 1998 27(6):1089 100 9652471
58 Perednia DA, Wallace J, Morrisey M, et al The effect of a teledermatology program on rural referral patterns to dermatologists and the management of skin disease Medinfo 1998 9(Pt 1):290 3 10384464
59 Taylor P An assessment of potential effect of a teledermatology system J Telemed Telecare 2000 6(Suppl 1):74 6
60 Loane MA, Gore HE, Bloomer SE, et al Preliminary results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial: Is clinical management by realtime teledermatology possible? J Telemed Telecare 1998 4(Suppl 1):3 5 9640716
61 Loane MA, Bloomer SE, Corbett R, et al Patient cost-benefit analysis of teledermatology measured in a randomized control trial J Telemed Telecare 1999 5(Suppl 1):S1 S3 10534821
62 Loane M, Bloomer S, Corbett R, et al A randomized controlled trial to assess the clinical effectiveness of both realtime and store-and-forward teledermatology compared with conventional care J Telemed Telecare 2000 6(Suppl 1):S1 S3 10793956
63 Olsson S, Busch C A national telepathology trial in Sweden feasibility and assessment Arch Anat Cytol Pathol 1995 43(4):234 41 8526558
64 Franken EA, Jr, Whitten P, Smith WL Teleradiology services for a rural hospital: a case study J Telemed Telecare 1996 2(3):155 60 9375050
65 Harrison PV, Kirby B, Dickinson Y, et al Teledermatology-high technology or not? J Telemed Telecare 1998 4(Suppl 1):31 2 9640726
66 Reid DS, Weaver LE, Sargeant JM, et al Telemedicine in Nova Scotia: Report of a pilot study Telemed J 1998 4(3):249 58 9831749
67 Cox R, York ML Rural telemedicine-the electronic signal flows in both directions. Best Pract Benchmarking Healthcare A Practical Journal for Clinical & Management Applications 1997 2(1):28 32
68 Finkelstein SM, Lindgren B, Prasad B, et al Reliability and validity of spirometry measurements in a paperless home monitoring diary program for lung transplantation Heart Lung 1993 22(6):523 33 8288456
69 Bruderman I, Abboud S Telespirometry: Novel system for home monitoring of asthmatic patients Telemed J 1997 3(2):127 33 10168278
70 Rissam HS, Kishore S, Srivastava S, et al Evaluation of cardiac symptoms by trans-telephonic electro-cardiographic monitoring (TTEM): Preliminary experience Indian Heart J 1998 50(1):55 8 9583288
71 Roth A, Carthy Z, Benedek M Telemedicine in emergency home care-the "Shahal" experience J Telemed Telecare 1997 3(Suppl 1):58 60 9218386
72 Mahmud K, Lenz J The personal telemedicine system. A new tool for the delivery of health care J Telemed Telecare 1995 1(3):173 7 9375138
73 Ahring KK, Ahring JP, Joyce C, et al Telephone modem access improves diabetes control in those with insulin-requiring diabetes Diabetes Care 1992 15(8):971 5 1505329
74 Billiard A, Rohmer V, Roques M, et al Telematic transmission of computerized blood glucose profiles for IDDM patients Diabetes Care 1991 14(2):130 4 2060415
75 Shultz EK, Bauman A, Hayward M, et al. Improved care of patients with diabetes through telecommunications. Ann N Y Acad Sci. 1992;670:141-5. [pmid: 1309083].
76 Friedman RH, Kazis LE, Jette A, et al A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control Am J Hypertens 1996 9(4 Pt 1):285 92 8722429
77 Johnston B, Wheeler L, Deuser J, et al. Outcomes of the Kaiser Permanente Tele-Home Health Research Project. Arch Fam Med. 2000;9:40-5. [pmid: 10664641].
78 Nakamura K, Takano T, Akao C The effectiveness of videophones in home healthcare for the elderly Med Care 1999 37(2):117 25 10024116
79 Keith R, Granger C, Hamilton B, et al. The functional independence measure: A new tool for rehabilitation. In: Eisenberg M, Grzesiak R, eds. Advances in Clinical Rehabilitation. New York: Springer-Verlag; 1987.
80 Sparks KE, Shaw DK, Eddy D, et al Alternatives for cardiac rehabilitation patients unable to return to a hospital-based program Heart Lung 1993 22(4):298 303 8360063
81 Piette JD, Mah CA The feasibility of automated voice messaging as an adjunct to diabetes outpatient care Diabetes Care 1997 20(1):15 21 9028687
82 Edmonds M, Bauer M, Osborn S, et al Using the Vista 350 telephone to communicate the results of home monitoring of diabetes mellitus to a central database and to provide feedback Int J Med Inf 1998 51(2-3):117 25
83 Bai J, Zhang Y, Dai B, et al The design and preliminary evaluation of a home electrocardiography and blood pressure monitoring network J Telemed Telecare 1996 2(2):100 6 9375070
84 Finkelstein J, Hripcsak G, Cabrera M Telematic system for monitoring of asthma severity in patients' homes Medinfo 1998 9(Pt 1):272 6 10384460
85 Lesher JL, Jr, Davis LS, Gourdin FW, et al Telemedicine evaluation of cutaneous diseases: ablinded comparative study J Am Acad Dermatol 1998 38(1):27 31 9448201
86 Loane MA, Corbett R, Bloomer SE, et al Diagnostic accuracy and clinical management by realtime teledermatology. Results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial J Telemed Telecare 1998 4(2):95 100 9744165
87 Oakley AM, Astwood DR, Loane M, et al Diagnostic accuracy of teledermatology: results of a preliminary study in New Zealand N Z Med J 1997 110(1038):51 3 9076285
88 Gilmour E, Campbell SM, Loane MA, et al Comparison of teleconsultations and face-to-face consultations: preliminary results of a United Kingdom multicentre teledermatology study Br J Dermatol 1998 139(1):81 7 9764153
89 Lowitt MH, Kessler, II, Kauffman CL, et al Teledermatology and in-person examinations: A comparison of patient and physician perceptions and diagnostic agreement Arch Dermatol 1998 134(4):471 6 9554300
90 Phillips CM, Burke WA, Allen MH, et al Reliability of telemedicine in evaluating skin tumors Telemed J 1998 4(1):5 9 9599075
91 Srikanthan VS, Pell AC, Prasad N, et al Use of fax facility improves decision making regarding thrombolysis in acute myocardial infarction Heart 1997 78(2):198 200 9326998 484904
92 Trippi JA, Kopp G, Lee KS, et al The feasibility of dobutamine stress echocardiography in the emergency department with telemedicine interpretation J Am Soc Echocardiogr 1996 9(2):113 8 8849606
93 Lee JK, Renner JB, Saunders BF, et al Effect of real-time teleradiology on the practice of the emergency department physician in a rural setting: initial experience Acad Radiol 1998 5(8):533 8 9702263
94 Tachakra S, Freij R, Mullett S, et al Teleradiology or teleconsultation for emergency nurse practitioners? J Telemed Telecare 1996 2(Suppl 1):56 8 9375093
95 Hubble JP, Pahwa R, Michalek DK, et al Interactive video conferencing: A means of providing interim care to Parkinson's disease patients Mov Disord 1993 8(3):380 2 8341308
96 Pacht ER, Turner JW, Gailiun M, et al Effectiveness of telemedicine in the outpatient pulmonary clinic Telemed J 1998 4(4):287 92 10220468
97 Baur DA, Pusateri AE, Kudryk VL, et al Accuracy of orthognathic evaluation using telemedicine technology Telemed J 1998 4(2):153 60 9710647
98 Pedersen S, Hartviksen G, Haga D Teleconsultation of patients with otorhinolaryngologic conditions: A telendoscopic pilot study Arch Otolaryngol Head Neck Surg 1994 120(2):133 6 8297568
99 Montani C, Billaud N, Couturier P, et al Telepsychometry: A remote psychometry consultation in clinical gerontology: Preliminary study Telemed J 1996 2(2):145 50 10165357
100 Hayes WS, Tohme WG, Komo D, et al A telemedicine consultative service for the evaluation of patients with urolithiasis Urology 1998 51(1):39 43 9457286
101 Bailes JE, Poole CC, Hutchison W, et al Utilization and cost savings of a wide-area computer network for neurosurgical consultation Telemed J 1997 3(2):135 9 10168279
102 Goh KY, Lam CK, Poon WS The impact of teleradiology on the inter-hospital transfer of neurosurgical patients Br J Neurosurg 1997 11(1):52 6 9156019
103 Eljamel MS, Nixon T The use of a computer-based image link system to assist inter-hospital referrals Br J Neurosurg 1992 6(6):559 62 1472322
104 Brecht RM, Gray CL, Peterson C, et al The University of Texas Medical Branch-Texas Department of Criminal Justice Telemedicine Project: findings from the first year of operation Telemed J 1996 2(1):25 35 10165347
105 Navein J, Hagmann J, Ellis J Telemedicine in support of peacekeeping operations overseas: an audit Telemed J 1997 3(3):207 14 10174345
106 Shanit D, Cheng A, Greenbaum RA Telecardiology: supporting the decision-making process in general practice J Telemed Telecare 1996 2(1):7 13 9375036
107 Johnson MA, Davis P, McEwan AJ, et al Preliminary findings from a teleultrasound study in Alberta Telemed J 1998 4(3):267 76 9831751
108 Brennan JA, Kealy JA, Gerardi LH, et al A randomized controlled trial of telemedicine in an emergency department J Telemed Telecare 1998 4(Suppl 1):18 20 9640721
109 Wootton R, Bloomer SE, Corbett R, et al. Multicentre randomised control trial comparing real time teledermatology with conventional outpatient dermatological care: societal cost-benefit analysis. Br Med J. 2000;320:1252-6. [pmid: 10797038]. [pmcid: 27370].
110 Goh KY, Tsang KY, Poon WS Does teleradiology improve inter-hospital management of head-injury? Can J Neurol Sci 1997 24(3):235 9 9276110
111 Moore RG, Adams JB, Partin AW, et al Telementoring of laparoscopic procedures: initial clinical experience Surg Endosc 1996 10(2):107 10 8932609
112 Lambrecht CJ, Canham WD, Gattey PH, et al Telemedicine and orthopaedic care. A review of 2 years of experience Clin Orthop 1998(348):228 32
113 Allen A, Hayes J Patient satisfaction with teleoncology: a pilot study Telemed J 1995 1(1):41 6 10165321
114 Montani C, Billaud N, Tyrrell J, et al Psychological impact of a remote psychometric consultation with hospitalized elderly people J Telemed Telecare 1997 3(3):140 5 9489108
115 Couturier P, Tyrrell J, Tonetti J, et al Feasibility of orthopaedic teleconsulting in a geriatric rehabilitation service J Telemed Telecare 1998 4(Suppl 1):85 7 9640749
116 Doze S, Simpson J, Hailey D, et al Evaluation of a telepsychiatry pilot project J Telemed Telecare 1999 5(1):38 46 10505368
117 Ricci MA, Knight SJ, Nutter B, et al Desktop telemedicine in vascular surgery: some preliminary findings Telemed J 1998 4(4):279 85 10220467
118 Clarke PH A referrer and patient evaluation of a telepsychiatry consultation-liaison service in SouthAustralia J Telemed Telecare 1997 3(Suppl 1):12 4 9218368
119 Bergmo TS An economic analysis of teleconsultation in otorhinolaryngology J Telemed Telecare 1997 3(4):194 9 9614733
120 Burgiss SG, Julius CE, Watson HW, et al Telemedicine for dermatology care in rural patients Telemed J 1997 3(3):227 33 10174347
121 Loane M, Wootton R. Cost-effectiveness in telemedicine[abstract]. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999 June 6-10; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 68.
122 Doolittle GC, Harmon A, Williams A, et al A cost analysis of a tele-oncology practice J Telemed Telecare 1997 3(Suppl 1):20 2 9218371
123 Cameron AE, Bashshur RL, Halbritter K, et al Simulation methodology for estimating financial effects of telemedicine in West Virginia Telemed J 1998 4(2):125 41 9710645
124 Stoeger A, Strohmayr W, Giacomuzzi SM, et al A cost analysis of an emergency computerized tomography teleradiology system J Telemed Telecare 1997 3(1):35 9 9139759
125 Darkins A, Dearden CH, Rocke LG, et al An evaluation of telemedical support for a minor treatment centre J Telemed Telecare 1996 2(2):93 9 9375069
126 Maass M, Kosonen M, Kormano M. Outcomes of a teleneuroradiological consultation network with Turku University central hospital and three regional hospitals[abstract]. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999 June 6-10; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 78.
127 Armstrong IJ, Haston WS Medical decision support for remote general practitioners using telemedicine J Telemed Telecare 1997 3(1):27 34 9139758
128 McLaren P, Ball CJ Telemedicine: lessons remain unheeded Br Med J 1995 310(6991):1390 1 7787547
129 Stevens A, Milne R, Lilford RJ, et al. How do new technologies get into practice? Keeping pace with new technologies: systems needed to identify and evaluate them. Br Med J. 1999;319:1291-5. [pmid: 10559044]. [pmcid: 1129069].
130 Lilford RJ, Braunholtz DA, Greenhalgh R, et al Trials and fast changing technologies: the case for tracker studies Br Med J 2000 320(7226):43 6 10617532 1117318
131 Technology ... telemedicine project to monitor renal dialysis patients Hosp Health Netw 1997 71(8):
132 Levine BA, Cleary KR, Norton GS, et al Experience implementing a DICOM 3.0 multivendor teleradiology network Telemed J 1998 4(2):167 75 9710649
133 Wheeler T Tele-ophthalmology: a tale of seven programs Telemed Today 1998 6(3).
134 Federal Telemedicine Directory 1998.
135 McCormack J Innovators 1998. Making eye care more accessible Health Data Manag 1998 6(7):40 2
136 Vassallo DJ, Buxton PJ, Kilbey JH, et al The first telemedicine link for the British Forces J R Army Med Corps 1998 144(3):125 30 9819718
137 Richardson RJ, Goldberg MA, Sharif HS, et al Implementing global telemedicine: experience with 1097 cases from the Middle East to the USA J Telemed Telecare 1996 2(Suppl 1):79 82 9375101
138 Houston M, Myers J, Levens S, et al Clinical consultations using store-and-forward telemedicine technology Mayo Clin Proc 1999 74(8):764 9 10473351
139 Darkins A, Fisk N, Garner P, et al Point-to-point telemedicine using the ISDN J Telemed Telecare 1996 2(Suppl 1):82 3 9375102
140 Halvorsen PA, Kristiansen IS Radiology services for remote communities: cost minimisation study of telemedicine Br Med J 1996 312(7042):1333 6 8646045
141 Rissam HS, Kishore S, Bhatia ML, et al. Trans-telephonic electro-cardiographic monitoring (TTEM)-first Indian experience. Stud Health Technol Inf. 1998;50:361-3.
142 Finkelstein J, Hripcsak G, Cabrera MR. Patients' acceptance of Internet-based home asthma telemonitoring. Proceedings/AMIA Annual Symposium. 1998:336-40.
143 Callahan EJ, Hilty DM, Nesbitt TS Patient satisfaction with telemedicine consultation in primary care: comparison of ratings of medical and mentalhealth applications Telemed J 1998 4(4):363 9 10220477
144 Pedersen S, Holand U Tele-endoscopic otorhinolaryngological examination: preliminary study of patient satisfaction Telemed J 1995 1(1):47 52 10165322
145 McLaren P, Ball CJ, Summerfield AB, et al An evaluation of the use of interactive television in an acute psychiatric service J Telemed Telecare 1995 1(2):79 85 9375124
146 Rosengren D, Blackwell N, Kelly G, et al The use of telemedicine to treat ophthalmological emergencies in rural Australia J Telemed Telecare 1998 4(Suppl 1):97 9 9640754
147 Loane MA, Bloomer SE, Corbett R, et al Patient satisfaction with realtime teledermatology in Northern Ireland J Telemed Telecare 1998 4(1):36 40 9640708
148 Huston JL, Burton DC Patient satisfaction with multispecialty interactive teleconsultations J Telemed Telecare 1997 3(4):205 8 9614735
149 Harrison R, Clayton W, Wallace P Can telemedicine be used to improve communication between primary and secondary care? Br Med J 1996 313(7069):1377 80 discussion 80-1 8956708
150 Whitten P, Collins B Nurse reactions to a prototype home telemedicine system J Telemed Telecare 1998 4(Suppl 1):50 2 9640735