# Recommendations for Future Research

## Selecting Priorities

Prioritizing research needs is an important, early step in evaluating telemedicine. Commonly used criteria for prioritizing effectiveness research are listed below. Programs with high research priority should:

- Address common, serious clinical conditions that require frequent contact with the health care system that often place a heavy burden onthe patient that limits the effectiveness of care.
- Address clinical procedures and circumstances for which components of care can be performed remotely. Examples include store-and-forward teleradiology and telepathology, remote wound-management, home health care delivered by a nurse, frequent reviewof laboratory parameters, and revision of management (e.g., medication use) in patients with chronic conditions.
- Aim to reduce medical errors in diagnosis ormanagement.
- Extend the capacity of the health care system to provide care to populations for whom barriers to access have been shown to affect indicators of health outcome and quality of care.
- Promote other policy goals, such as strengthening rural health care by keeping care local.
- Priority-setting for effectiveness studies should also consider the degree of uncertainty about benefits, harms, and costs, and the likelihood that the research will have an impact.

## Need for Experimental Designs and Registry Methods

The need for randomized controlled trials to establish the effectiveness of new technologies is widely accepted. Well-done trials can ensure early adoption of techniques that are clearly cost-effective and early detection of problems that need to be corrected. Large, inclusive, observational studies that measure the effect of providing a service on population-based measures of utilization, access, and outcomes are also important because they provide information about how a particular service performs in actual practice. These designs, properly reviewed by experienced investigators in study sections, offer a higher potential to provide high-quality information about effectiveness than do demonstration projects.

Rapid change in telecommunications technology is frequently cited as an important barrier to conducting randomized trials of telemedicine services. Some telemedicine advocates caution against starting trials too early, before they have had time to detect and address system problems or an effective implementation strategy. Others note that, by the time a randomized trial is designed and funded, not to mention completed, the targeted intervention may already have changed substantially.

While designing studies of emerging technologies is not simple, it can be accomplished. In fact, evaluating the clinical impact of atelemedicine service beginning with the first patients it is used for has several advantages. First, starting aregistry or trial when technology is still changing "ensures maximum use of information after it has stabilized."^ 130 ^ Second, when technical performance and operator skill are important components of effectiveness, they are part of the intervention and should be studied. Such a design prevents selective reportingof only the best results of a given application, a bias which is a common flaw in existing studies. Over time, a registry containing all clinicians who provide these services, and all patients who use them, can provide important data about the evolution of the technique and about the "learning curve" for clinicians who might want to adopt the service in their practices. Second, for patients who are also Medicare beneficiaries, a registry is necessary to measure subsequent utilization that is prompted or averted by the service.

The fact that telemedicine is evolving thus makes it more important to assess its impact systematically. Telemedicine is an ideal topic for innovative experimental designs that are adapted to rapidly changing technologies. Recently, techniques to adapt randomized trial design to rapidly changing interventions have been proposed. For example, a "tracker trial" is guided by flexible protocols and offers the opportunity to add or drop arms as clinically available options for delivering a service emerge and others become obsolete.^ 130 ^ The use of this approach, or other innovative approaches to studying technologies that change rapidly, should be incorporated into future research about telemedicine.

## Basic Research To Inform Telemedicine

Along with telecommunication technology itself, the characteristics of the patients studied and the judgment of an individual physician, often a specialist, are major components of the clinical intervention in telemedicine. The results of an evaluation will be more generalizable to other patients and to clinicians in other settings if the characteristics of the patient population are defined and the judgments of the study physicians are consistent and reproducible. Most studies have focused on recruitment of participating clinicians rather than identifying a target patient population, selected because of the potential to improve outcomes via better access to care.

From the viewpoint of informatics, then, there is a need for basic research to inform the implementation of telemedicine programs. This research should:

- Refine the target population for telemedicine services. This research should address: - The burden of disease attributable to poor accessto specialty care. - Barriers to access that coincide with (and might affect the impact of telemedicine services on) distance and mobility barriers. - Identification of groups that are most likely to benefit from specific telemedicine services. Clinical studies should examine differences in effectiveness and cost-effectiveness based on the circumstances of the use of telemedicine. The research should examine the relationship between the effectiveness of telemedicine services and characteristics, health needs, and barriers to access of rural poor, inner-city poor, and other populations.
- Refine clinical interventions prompted by telemedicine services. This research should: - Develop and validate protocols, including computer-assisted decision tools, to use self-monitoring and testing information effectively in reducing preventable hospitalizations and improving functional outcomes. - Examine strategies for organizing telemedicine services in a way that reduces the burden on participating practitioners. Specifically, we recommend developing a request for proposals to explore ways to implement telemedicine services in the context of community-based primary care practices. This can be best accomplished by conducting this research in association with primary care practice networks. In the past, most telemedicine research involving a referring primary care physician has used small convenience samples of clinicians. Primary care practice networks are the "laboratory" for conducting research about practice management, for designing research that minimizes the disruption to the flow of practice, and for examining the effects of innovative services in community-based practice settings.
- Develop or adapt standardized tools to measure the effectiveness and harms of telemedicine services.
- Explore different mechanisms for delivery and payment for telemedicine services, assessing their impact on utilization in atarget population of patients.

## Recommendations for Specific Studies

### Store-and-Forward Telemedicine

- A prospective trial should be done to compare the performance of store-and-forward teledermatology versus interactive teledermatology. The study design should compare the two telemedicine modalities to in-person examination and assess inter-observer variation among all of the modalities - i.e., compare one person's store-and-forward or in-person diagnostic assessment with that of another usingthe same modality.
- Within the population of Medicare beneficiaries, aquasi-experimental design in which assignment to conventional or teledermatologic services was made by geographic region or by self-selection could provide useful information about costs and, in particular, about the effect of telemedicine coverage on acceptance, satisfaction of patients and providers, and total utilization. Morbidity from dermatologic diseases would be an important measure of outcome in such a study. Even a very large trial, however, would be unlikely to show an effect on mortality from invasive dermatologic malignancies, but an effect on the stage at which cancers were detected should be measured.

### Self-Monitoring/Testing Telemedicine

- Because it targets high-volume, serious conditions -- such as diabetes, congestive heart failure, and management of anticoagulation therapy -- an effective self-monitoring/testing application could offer asubstantial benefit. There are sufficient data from small trials and from observational trials to merit a more definitive assessment of efficacy in large randomized trials.
- We propose a randomized controlled trial of telemedicine monitoring of patients with congestive heart failure. Congestive heart failure is the only major heart disease for which mortality is increasing, and it will likely continue to do so as the American population ages. Many self-monitoring/testing interventions can be done for patients with congestive heart failure. These patients generate much data, such as weight, fluid input and output, and description of symptoms (e.g., orthopnea and pedal edema). They may benefit from frequent communication with, as well as observation by, their health care providers. Moreover, morbidity from congestive heart failure, including admission to the hospital for exacerbations, has been associated with poor access to care and substantial reductions in quality of life. The major outcome measures would include mortality, functional status assessment, and hospitalization requirements. The cost-effectiveness evaluation should include the costs of the monitoring, as well as all physician office visits, emergency room visits, and hospitalizations related to the heart failure. The incremental cost per life year of quality-adjusted life years for the telemedicine application should be estimated.

### Clinician-Interactive Services

- Well-done, registry-based, observational studies are needed to assess how telemedicine affects management decisions and how acceptable it is to broad populations of physicians and patients. As shown in Table 12 on pages 53 and 54, programs exist in many domains but little evidence exists to demonstrate efficacy for telemedicine. The acceptability and applicability of many of these services have not been evaluated. Once observational studies have provided strong evidence of effectiveness, randomized trials might focus on patient outcomes. Several clinical areas, including psychiatry, neurology (for Parkinson's disease and stroke care), otolaryngology, orthopedics, and others, merit additional research of this kind.
- We propose a randomized controlled trial to assess the benefit of telepsychiatry. While a substantial proportion of patients with depression and other psychiatric disorders can be managed in primary care, the frequency with which specialty care is needed is higher than for several other common conditions. Individuals with non-psychotic disorders severe enough to warrant a psychiatrist, such as those with severe depression or anxiety disorders, would be randomized to receive their care in-person or via telemedicine. Patients would receive care via one or the other modality, and outcome measures would assess clinical improvement (assessed by a blinded third party), as well as patient satisfaction. Costs of the telepsychiatry service should include the costs of the application and costs associated with all physician and emergency room visits, medications, and hospitalizations for the specified condition. The cost-effectiveness can compare the cost per patient without serious exacerbation of the disorder. Alternatively, total cost of care may be an adequate measure, since higher total costs are likely to be driven by either hospitalizations or intense physician treatment of a worsening of the disorder.

## Other Recommendations for Research

Editors of scientific journals might also play a role in improving the quality of studies that evaluate telemedicine technology. The telemedicine literature we reviewed, whether in core or clinical specialty journals, is riddled with studies that describe creative uses of technology but feature a low-quality evaluation study. We recommend that journal editors decline to publish these low-quality evaluations and instead let the technologists publish their technology descriptions and allow their technology-assessment collaborators to carry out appropriate evaluations.

## Conclusions on Future Research

A large number of gaps remain in both efficacy and effectiveness research concerning access, satisfaction, quality of care, cost, and cost-effectiveness of telemedicine applications. The body of current knowledge surveyed in this review provides sufficient evidence that new, better-designed studies need to be undertaken. With the availability of telemedicine programs throughout the United States expanding rapidly, the demand for the technology has already begun to grow, even without compelling evidence to demonstrate its efficacy orcost-effectiveness. This leaves thepolicy-makers with the difficult question of how to deal with this growing field. Given that demand, it seems equally compelling that some significant resources should be expended proposing, funding, designing, implementing, and reporting on this intriguing question.