# Results

## Overview of Current Telemedicine Programs

We identified 455 telemedicine programs(see Figure 5), of which 362 are in the United States. Most telemedicine programs werestarted in 1993 or later, with more programs started in 1995 than in any otheryear. Among programs located in the United States, 111 are located at academic medical centers and 68 are in hospital-based healthcare networks; 80 are Federal military or Veterans Affairs (VA) medicalcenters. Over 30 medical specialtiesare represented.

Figure 5. World telemedicine programs

>

Figure 6 shows the geographic location of the most common clinical specialties of telemedicine programs in the United States. The activities most common totelemedicine programs in our database are consultations or second opinions (290 programs), diagnostic test interpretation (169 programs), chronic diseasemanagement (130 programs), post-hospitalization or post-operative follow-up (102 programs), emergency room triage (95 programs), and "visits" by aspecialist (78 programs). About 50programs provide services in patients' homes.

Figure 6. U.S. telemedicine programs

>

Telemedicineis capable of reaching many diverse populations. As expected, more telemedicine programs serve rural patients thanany other group of people. Of the 455 programs discovered in our general-literature review, approximately 120 (26 percent) provide health care to rural populations. Telemedicine also serves alarge number of veterans. Forty-one VA Medical Centers have implemented telemedicine into their health care services, representing approximately 9 percent of all telemedicine programs. The third-most commonly targeted population is the elderly. Many programs serve older patients in the process of providing care to diverse populations, but 12 focus specifically on providing care for the elderly. Corrections systems have alsoused telemedicine for diagnosis and treatment of prisoners, reducing the costand risk of transporting a prisoner to a medical center. Finally, several programs successfully treatlow-income, urban people. Although these programs do not represent a large percentage of all telemedicine programs, they are significant because they show that telemedicine is capable of improving health care access for many different types of patients, even when distance is not the primary barrier to receiving medical care.

The numbers of telemedicine encounters performed has increased steadily throughout the 1990s, with significantly more consults in 1997 and 1998 than in previous years.^ 4 ^ Individual telemedicine programs generally do not show consistent changes in their usage from year to year. In fact, one commontrend is a sudden decline in the number of telemedicine encounters. For example, Methodist Hospital in Indianapolis, Indiana performed 302 tele-cardiology consults in 1997 and 87 in 1998 (72 percent reduction). The Eastern Montana Telemedicine Network in Billings decreased its number of mental health telemedicine encounters from 985 in 1997 to 248 in 1998 (75 percent reduction). The Louisiana Telemedicine Program in New Orleans performed 120 interactive video neurology telemedicine encounters in 1997 and only 38 in 1998 (68 percent reduction). A few other programs report sudden increases in the number of consultations. At the Center for Telemedicine at the University of Oklahoma Health Sciences Center, for example, the number of store-and-forward ophthalmology telemedicine encounters rose from 100 in 1997 to 617 in 1998. One likely reason for these abrupt shifts is the sudden termination or influx of funding, since much of the funding for telemedicine programs comes from federal, state, and local government and private grants. Another possible reason is the sudden departure of a champion physician who can account for a large percentage of a program's use.

## Quality Standards, Clinical Qualifications, and Data Systems

There is general agreement that well-formulated, comprehensive standards are needed to ensure the safety and reliability of telemedicine services. Standards should address several issues that influence safety, including reliability, image or sound quality, procedures to deal with system failures, protection of confidentiality, and qualifications and certification of personnel.^ 38 ^

The American College of Radiology (ACR) standards for teleradiology (http://www.acr.org/f-sitemap.html) might well serve as a model for other telemedicine specialties. The ACR standards specify qualifications of personnel, equipment guidelines, licensing, credentialing, quality control, andquality improvement for teleradiology. The standards are complex and have been developed over a decade. The Digital Imaging and Communication in Medicine Standard (DICOM), which enables interoperability of digital imaging equipment from different manufacturers, is a critical part of the ACR standards.

Standards for other telemedicine specialties are still in their infancy. Published reports from telemedicine programs frequently describe the type of equipment, resolution of images, and qualifications of personnel, but none of these is standardized within activity or specialty. Although many programs report tracking data, the papers provide little information on how data were collected or whether the quality of the data was audited. Programs use a wide variety of data systems, most of them locally developed,^39-41^ to track activities. The ability of these systems to identify system failures, such as interrupted or corrupted transmission of information, has not been reported inthe literature.

Two well-designed papers that describe the development of in-house technicalstandards for tele-urology and telenephrology applications^42, 43^ identify two barriers to the development of standards. First, technical requirements for image or sound quality are different for each application. Second, working out these requirements for even a single, narrowly focused application is highly complexand requires an intense effort.

## Overview of Peer-Reviewed Studies

The literature searching and other identification of studies found 177 articles with possible evidence for addressing one or more of the analytic framework questions and applying to one or more of the three study areas. Several articles applied to more than one analytic framework question and/or more than one of the three study areas. Table 6 lists included and excluded articles for each of the analytic framework questions for the three study areas. There were many more studies for clinician-interactive telemedicine than for store-and-forward or self-monitoring/testing telemedicine. However, there were more articles on health outcomes inself-monitoring/testing telemedicine than the other two study areas.

Table 6. Included and excluded articles for each of the analytic framework questions for the three study areas

| Unique articles | Diagnosis and management | Access | Outcomes | Satisfaction | Cost
Store-and-forward | 15
Included | | 10 | 2 | 1 | 2 | 4
Excluded | | 32 | 1 | 0 | 0 | 4
Self-monitoring/testing | 14
Included | | 3 | 2 | 8 | 6 | 3
Excluded | | 1 | 0 | 10 | 1 | 1
Clinician-interactive | 48
Included | | 19 | 8 | 7 | 26 | 14
Excluded | | 5 | 3 | 4 | 14 | 14

We included 15 articles that assessed store-and-forward telemedicine. Some articles reported on applications that were not true store-and-forward but could easily have been adapted to this mode. Fourteen unique articles evaluated self-monitoring/testing applications. Forty-eight articles assessed clinician-interactive services. Nine randomized controlled trials were identified for the study population, one for store-and-forward, six for self-monitoring/testing, and two for clinician-interactive.

Appendix E lists articles that were excluded for each of the major analytic framework questions. Studies were too heterogeneous and of varying quality to undertake any quantitative aggregate analysis, i.e., meta-analysis.

## Store-and-Forward

Our analysis of store-and-forward telemedicine assessed the capability and efficacy of store-and-forward consultations, organizing our findings around several key questions (see Figure 2, page 20). The analysis focuses on the use of pure (i.e., asynchronous) store-and-forward telemedicine. The literature reviewed suggests a current state-of-the-art approach to store-and-forward telemedicine would typically include digital audio (e.g., an electronic stethoscope) and/or video modalities (a digital camera with greater than 1,000-by-1,000-pixel display and 24-bit color), along with the ability to record patient history and physical examination data (in free text or captured via structured data entry from anelectronic medical record). This material would later be transmitted using telecommunications medium. While that medium might beanalog telephone lines using a modem, there is growing proliferation of broadband services (e.g., frame relay, cable modem, digital subscriber line) that allow faster transmission. At the receiving end, consultants are likely to have access to high-powered workstations with high-resolution displays, allowing access to textual data, audio, and video in an integrated fashion. The findings and recommendations of the consult would likely be transmitted back to the clinician via e-mail or fax.

An overall summary of programs and evidence is shown in Table 7. Each row represents a clinical specialty for which at least one store-and-forward telemedicine program exists, with theorder determined by the number of programs in that specialty. In the rightmost five columns are brief synopses of the evidence for the major analytic framework questions. If a cell is blank it indicates that no studies assessing store-and-forward telemedicine in that specialty have been done.

Table 7. Summary of evidence for store-and-forward telemedicine

Clinical Specialty^1^ | Diagnosis/Management | Access | Outcomes | Satisfaction | Cost
Cardiology | Outpatient exam diagnostic agreement comparable to in-person (II-C)
Dermatology | Diagnostic accuracy and management decisions comparable with in-person consultation (I-A) | Access to services improved with availability of telemedicine (II) | Requires more follow-up visits than interactive teledermatology or in-person exam (III-B) | Weak evidence for increased patient satisfaction (III-B) | Weak evidence for decreased costs (<2 of 6-B)
Orthopedics | Outpatient exam diagnostic agreement comparable to in-person (II-C)
Mental Health
Ophthalmology | Good agreement with in-person exam for HIV disease, less for diabetes mellitus (II-C)
Neurology
Pulmonary Care
Nutrition
Endocrinology | Outpatient exam diagnostic agreement comparable to in-person (II-B)
Gastroenterology Emergency/Triage | | | | | Cost benefits limited by study design (4 of 5-C)
Oncology/Hematology
Specialty Surgery
Primary Care
General Surgery
Infectious Disease
Neuroradiology
Otolaryngology | Better diagnostic and management agreement with real-time telemedicine than store-and-forward (II-B)
Nuclear Medicine
Plastic Surgery | Good agreement for assessment of skin wounds (II-B)
Nephrology
Oral/Maxillofacial Surgery
Obstetrics/Gynecology
Genetic Counseling
Urology
Rehabilitation Counseling
Rheumatology
Internal Medicine
Speech Pathology
Dentistry
Other

1 Each row represents a clinical specialty for which at least one store-and-forward telemedicine program exists, with the order determined by the number of programs in that specialty.

2 Shaded areas indicate that no studies assessing store-and-forward telemedicine in that specialty have been done.

It can be seen that while programs operate in many clinical domains, studies assessing the efficacy are lacking in most of them. Furthermore, for many settings where studies have been done, the evidence for efficacy is of insufficient quality to judge how well store-and-forward telemedicine works. Overall, teledermatology is the most-studied clinical specialty in store-and-forward telemedicine; its diagnosticaccuracy and patient-management decisions are comparable to those of in-person clinical encounters. It may improve access to care and have adequate patient acceptance. In a few other areas there is weak evidence for efficacy of comparable diagnostic ability.

### Key Question 1a. To what extentdoes store-and-forward telemedicine have the same components as a traditionalclinical encounter?

Store-and-forward telemedicine encounters are being done in many specialties, but differ from face-to-face consultations.

#### What types of encounters are being done?

In 1997, about 12,000 encounters were done using store-and-forward applications.^ 5 ^ We identified 186 activities within 117 programs use store-and-forward telemedicine. A total of 70 activities use store-and-forward exclusively, while the remainder use it in association with other technologies, such as video conferencing. The most common clinical specialties using store-and-forward technology are listedin Table 8, with the most common activities shown in Table 9.

Table 8. Clinical specialties of store-and-forward telemedicine programs

Clinical specialty | Number of programs
Radiology | 39
Cardiology | 20
Dermatology | 19
Orthopedics | 14
Mental Health | 13
Ophthalmology | 11
Pathology | 9
Neurology | 7
Pulmonary Care | 5
Nutrition | 4
Endocrinology | 4
Gastroenterology | 4
Emergency/Triage | 3
Oncology/Hematology | 3
Specialty Surgery | 3
Primary Care | 2
General Surgery | 2
Infectious Disease | 2
Neuroradiology | 2
Pediatrics | 2
Otolaryngology | 2
Nuclear Medicine | 1
Plastic Surgery | 1
Nephrology | 1
Oral/Maxillofacial Surgery | 1
Obstetrics/Gynecology | 1
Genetic Counseling | 1
Urology | 1
Rehabilitation Counseling | 1
Rheumatology | 1
Internal Medicine | 1
Speech Pathology | 1
Dentistry | 1
Other | 1

Table 9. Clinical activities of store-and-forward telemedicine programs

Clinical activity | Number of programs
Specialist Consults or Second Opinions | 31
Diagnostic Test Interpretation | 26
Emergency Room/Triage | 8
Specialist Visits | 6
Chronic Disease Management | 4
Post-Hospital/Post-Operative Follow-Up | 3
Primary Care | 2
Physiological Monitoring | 2
Home Health | 2
Rehabilitation | 1
Nutrition Consultation | 1
Nursing Home Care | 1

#### What type of information is transmitted?

Store-and-forward telemedicine typically provides the consultant with a report on the patient's history and physical examination, either from the original medical record or summarized on a form, along with digitized photographs, radiographs, or other images. Table 10 shows the characteristics of programs from which the details could be abstracted from published reports.

Table 10. Types of information transmitted from store-and-forward telemedicine programs

Program | Reference | Specialty | Clinical Activity | Data Provided
Georgetown University Med Center/ISIS, Washington. D.C. | Tohme, 1997,^ 42 ^ Anonymous, 1997,^ 131 ^ Levine, 1998^ 132 ^ | Urology | Specialty consult | Images, documented history and physical exam.
Georgetown University Med Center/ISIS, Washington. D.C. | Tohme, 1997,^ 42 ^ Anonymous, 1997,^ 131 ^ Levine, 1998^ 132 ^ | Nephrology | Specialist clinic | Dialysis data, stethoscope recording of heartbeat, images,
University of Houston Eye Institute Teleophthalomology, Houston, TX | Wheeler, 1997^ 133 ^ | Ophthalmology | Specialty consult | Images of eye, video clips of eye
Kaiser Permanente Teleophthalmology, Oakland, CA | Wheeler, 1997^ 133 ^ | Ophthalmology | Specialist clinic | Images of retina from Canon non-mydriatic fundus camera
Whiteman Airforce Base, Knob Noster, MO | Anonymous, 1998^ 134 ^ | Multiple, especially orthopedics, dermatology | Specialty consult | Images, documented history and physical exam.
Carmelitos Preventive Eye Care Center, Los Angeles, CA | McCormack, 1998^ 135 ^ | Ophthalmology | Specialty consult | Images of eye
Sipovo, Bosnia - Royal Hospital Haslar Telemedicine Link, Gosport, United Kingdom | Vassallo, 1998^ 136 ^ | Dermatology, plastic surgery, orthopedics, orology, ophthalmology, maxillo-facial surgery | Specialty consult | Digital photos, photos of x-rays, documented history and physical exam.
Massachusetts General Hospital Saudi Arabia Telemedicine, Boston, MA | Richardson, 1996^ 137 ^ | All specialties, especially orthopedics, neurosurgery, neurology, and cardiology | Specialty consult | Images, labs, documented history and physical exam
St. Louis Veterans Affairs Medical Center, St. Louis, MO | FTD, 1998^ 134 ^ | Nuclear medicine | Image reading | Images

#### How does the work of a teleconsultant differ from the work of a traditional consultant?

One reason store-and-forward telemedicine is controversial is that many specialists prefer to conduct their own history and physical examination, believing that these often provide essential information. These concerns about the completeness of the information provided for store-and-forward consultations are similar to concerns about "curbside" consultations^44-46^ and telephone care.^ 47 ^

Store-and-forward technology is commonly used to transmit radiographs and pathology specimens for interpretation. Store-and-forward technology is particularly well-suited to these specialties because radiologists and pathologists usually interpret these materials without a face-to-face encounter with the patient.

The use of store-and-forward as a substitute for face-to-face consultation is not as straightforward. Like a traditional consultant, the specialist performing a store-and-forward teleconsultation makes specific recommendations for managing the patient. In a conventional consultation, however, a history and physical examination are performed by the consultant, and this information is integrated with laboratory and imaging data to develop a diagnosis and management plan. Counseling and coordination of care may also be done. Store-and-forward teleconsultations do not include many of these components. Rather than conducting their own history and physical examination, consultants must rely on the referring physician's. The teleconsultant reviews this information along with the audio and video data to offer a diagnosis and management plan.

### Key Question 1b. Does store-and-forward telemedicine result in comparable diagnosis and appropriateness of recommendations for management?

We examined peer-reviewed studies toanswer two questions:

- How accurate is diagnostic interpretation of transmitted data in a store-and-forward teleconsultation?
- How do recommendations made after teleconsultation compare in quality to those made after face-to-face consultation?

The best evidence for the efficacy of store-and-forward telemedicine for diagnostic accuracy and appropriate management decisions comes from teledermatology, where several studies compare it to in-person examinations. There is some evidencethat it achieves comparable efficacy in otolaryngology, outpatient medicine, ophthalmology, and wound healing.

Evidence Table 1 lists the included studies that assess accurate diagnosis and appropriate management recommendations for store-and-forward telemedicine. The studies in the evidence table were rated based on the three-class (I-III) rating of diagnostic study methodology described in Table 4 (page 28). Aletter grade was also assigned to rate the direction of the effect (see Table 3, page 28).

#### Dermatology

Five studies assessed the diagnostic and/or management decision capability of teledermatology used in a store-and-forward capacity. No studies explicitly compared store-and-forward to interactive teledermatology.

Two store-and-forward studies compared diagnostic agreement between teleconsultation and in-person consultation to agreement among different in-person consultants. The first was carried outin a university general dermatology clinic.^ 48 ^ The store-and-forward consultation consisted of a brief statement of the patient history and appropriate images. In 308 patients, the concordance of store-and-forward versus in-person consultation (83 percent) was comparable with interdermatologist (81 percent) and intradermatologist (84 percent-two months later) rates. This study demonstrated that store-and-forward teledermatology can be as accurate for diagnosis as in-person consultation. It did not assess management decisions made by the dermatologists based on the diagnosis, nor did it assess patient outcomes.

The second study to assess intramodality as well as intermodality agreement was performed in a Department of Veterans Affairs clinic setting.^ 49 ^ This study compared diagnostic and management agreement among patients seen by five examiners, two in the clinic and three using digital images along with a standardized history form. Agreement on the exact diagnosis was 54 percent for the clinic dermatologists, 41-55 percent between the clinic and teledermatologists, and 49-55 percent among the teledermatologists. Higher concordance was obtained when partial agreement over a differential diagnosis was assessed. Agreement on overall management plans was 77 percent for the clinic dermatologists, 56-77 percent between the clinic dermatologists and teledermatologists, and 64-83 percent among the teledermatologists. For a subset of patients for whom adiagnosis was made with reference standard test, accuracy for exact diagnosiswas 59-71 percent for the clinic dermatologists and 53-62 percent for the teledermatologists. Most of the differences in agreement and accuracy were not statistically significant, indicating that diagnosis and management using store-and-forward teledermatology can be as reliable as in-person consultation. Power calculations were not reported with these results, so the lack of statistically significant differences could also have been due to inadequate sample size.

The other studies examined only intermodality agreement. One compared the history alone, images alone, and history-plus-images to diagnose and manage dermatology problems in nursing home patients.^ 50 ^ Having access to the history plus images achieved the best rate of correct diagnosis (88 percent) and management plans (90 percent). There was no comparison of the baseline rate of disagreement between the examiners, and all in-person gold standard diagnoses were determined by asingle dermatologist. Nonetheless, this study does provide evidence that store-and-forward teledermatology usually leads to appropriate diagnostic and management decisions.

Another study compared agreement in diagnoses between in-person dermatologists and teledermatologists who had access to the in-person examiner's history and digital images^ 51 ^ Concordance between in-person and remote examiners was 61-64 percent for the most likely diagnosis, with no difference across major diagnosis categories. Additional findings were that agreement was increased when the quality of the image was higher and the certainty of thein-person examiner of the diagnosis was stronger. This study was limited by the lack of statistical analysis and by the fact that the patient history was obtained by a dermatologist (as opposed to a primary care clinician).

An additional study compared correct diagnosing of skin biopsies between store-and-forward and in-person examiners.^ 52 ^ Because it included only patients who were already going to have a skin biopsy, this study has little relevance to the typical situation in which a teledermatology consult is needed. A more relevant decision point would be whether to obtain a biopsy in the first place. Such a study would also assess the adverse consequences of the decision to not pursue a skin biopsy when one was indicated.

#### Other Clinical Specialties

We identified six other studies that employed or could employ store-and-forward techniques for diagnosis and management. Two studies were from otolaryngology, while one each was from outpatient medicine, dental screening, ophthalmology, and wound healing.

One of the otolaryngology studies was the only study in our entire sample that cameclose to comparing store-and-forward to interactive consultation.^ 53 ^ This study compared whether in-person otolaryngology consults resulted in diagnostic agreement with two telemedicine approaches: a real-time but non-interactive viewer and a non-real-time viewer who had access to a printed report of findings and on-line images. The findings showed that the non-interactive real-time viewer agreed with the in-person diagnosis 85 percent of the time, while the store-and-forward viewer agreed with the in-person diagnosis only 64 percent of the time. In this instance, store-and-forward telemedicine was clearly inferior, although the real-time viewer was not performing a truly interactive consultation.

Another otolaryngology study showed a better result for the store-and-forward approach. It looked at remotely transmitted consultations consisting of text of the patient history and physical exam along with laryngoscopy images.^ 54 ^ There was diagnostic agreement between the on-site and remote otolaryngologists for all 29 cases. Neither of the otolaryngology studies assessed management decisions.

The outpatient medicine study looked at telemedicine encounters performed on 20 patients from four specialties -- cardiology, dermatology, endocrinology, and orthopedics.^ 55 ^ Fifteen of these patients also had a face-to-face encounter. For those having both store-and-forward and in-person exams, there was complete agreement on diagnoses, though each modality led to some change in management.

The ophthalmologic study of HIV patients and diabetes patients actually used interactive telemedicine, but a good visualization of the eye by the remote examiner could have been done in a store-and-forward fashion.^ 56 ^ This study showed that ophthalmologic examination by telemedicine had a high sensitivity and specificity for identifying findings in patients with HIV disease, but much poorer results for findings in diabetic patients, usually due to the presence of cataract.

Since some individuals with major skin wounds travel at considerable discomfort and expense for medical observation, they may put off the visits and thus delay healing. A study of wound healing, carried out in the hospital setting, could be extrapolated to the setting of the referring primary care physician.^ 57 ^ This study assessed agreement of diagnostic and management plans between in-person andremote consultations. It showed relatively good sensitivity and specificity of appropriate diagnostic observations and management plans.

### Key Question 1c. Does the availability of store-and-forward telemedicine provide comparable access tocare?

The only studies to assess patient access issues for store-and-forward telemedicine came from teledermatology, where some evidence suggests that better access to dermatology consultations is possible using this technology.

One teledermatology study demonstrated increased utilization after a store-and-forward teledermatology service was deployed in rural areas.^ 58 ^ Before installation of the teledermatology system, the baseline rate of consultation was 1.8 percent of all skin problems seen by the local primary care physician. At 4-6 months after installation, the rate of teledermatology consultation jumped to 9.6 percent of all skin problems. Even the rate of in-person dermatology consultation increased to 3.6 percent. However, at 10-12 months, the consultation rate leveled off to 2.8 percent for teledermatology and 0.2 percent for in-person consultations, which together still add up to a higher rate than the baseline.

Another study^ 59 ^ addressed the effect of telemedicine on dermatology consultation utilization, interpreted as appointment triage decisions (i.e., urgent, routine, or never), but the quality of this study was very limited. Triage decisions made from a referral letter were compared with triage decisions made 13 months later from skin-condition images obtained near the time of the letter for the same patients (although the length of time between referral letter and image photography was not reported). Some flaws were no descriptions of the sample selection procedures or sample characteristics; no reported inter-rater reliability between the two consultant raters; no definitions of the triage-rating measures; use of different rating scales for each set of triage assessments that were compared; a discrepancy in the reported outcome rate (stated differently in the text and the table); and no reported significance levels. Since the investigator did not indicate which triage decisions would be seen by a consultant, it was also not possible to estimate the effect of telemedicine on access to a dermatologist.

### Key Question 2. What are the potentialadverse effects of store-and-forward telemedicine?

Potential adverse effects of store-and-forward telemedicine include the consequences of technical problems, of false-positive or false-negative interpretation of diagnostic information, and of overutilization. While these issues are frequently mentioned in editorial and news items, they have received little or no attention in research studies.

Store-and-forward teleconsultation may change the intensity of work performed by the referring physician. The referring physician's office has to arrange for the patient's medical history, physical examination report, and any telemedicine imaging to be collected and transferred to the teleconsultant. Collecting this information for store-and-forward telemedicine encounters has been reported in several studies to be more time-consuming than in-person consults for both referring and consulting physicians.^55,60,61^

### Key Question 3. Does store-and-forward telemedicine lead to comparable health outcomes?

We found no studies that assessed health outcomes using store-and-forward telemedicine. One study assessed "clinical outcome," which was defined as the need to have a follow-up appointment with a hospital-based specialist.^ 62 ^ Store-and-forward consultations were found to require more follow-up visits (69%) thaninteractive teledermatology consultation (46%) or in-person consultation (45%). No statistical analysis of the differences was performed.

### Key Question 4. Does store-and-forward telemedicine lead to comparable patientor clinician satisfaction with care?

Measures of patient or provider satisfaction with store-and-forward telemedicine were incorporated into four studies. Two studies of provider satisfaction were from excludeddomains -- telepathology^ 63 ^ and teleradiology.^ 64 ^ However, we found no information by which to evaluate provider satisfaction with the store-and-forward telemedicine applications of most interest to this report.

As with provider satisfaction, there was not enough reported evidence to determine whether patients are as satisfied with store-and-forward telemedicine as they are with face-to-face encounters with specialists. Two studies that reported patient satisfaction concerned teledermatology. Zelickson and Homan,^ 50 ^ in a study of teledermatology in a nursing homesetting, asked patients and/or their guardians to rate their satisfaction with the service. Only 23 percent of those surveyed returned the questionnaires. Harrisonet al.,^ 65 ^ in a study in a dermatology clinic, also received alow return rate (24 percent) on their satisfaction questionnaire. Although both studies reported high rates of patient/guardian satisfaction with teledermatology, the low response rate limits the inferences that can be drawn from the data.

### Key Question 5. Does store-and-forward telemedicine lead to comparable costs of care?

Evidence Table 2 summarizes study characteristics, quality ratings, and results of economic evaluations. Only two papers, both in the area of teledermatology, reported on store-and-forward costs. Zelickson and Homan^ 50 ^ analyzed program costs for 30 consecutive dermatology teleconsultations in a nursing home in Minnesota. However, they reported only the total cost for the dermatology teleconsults and the per-visit costs for the in-office and in-nursing-home consults. Reid et al.^ 66 ^ reported on several pilot telemedicine applications in Nova Scotia, Canada. For adermatology teleconsultation they reported only a cost of Can$160, but made no comparison to the costs of traditional care.

### Key Question 6. Is store-and-forward telemedicine cost-effective?

We identified no studies of the marginal cost-effectiveness of store-and-forward telemedicine.

### Summary

Table 7 summarizes store-and-forward telemedicine programs and evidence about its effectiveness. Very little peer-reviewed literature evaluates the use of store-and-forward telemedicine in a controlled manner. The best evidence for diagnostic accuracy isin teledermatology, where two studies demonstrate that the rate of concordancefor diagnostic assessment equals the rate of agreement among in-person dermatologists.^48, 49^ One of these^ 49 ^ also shows a comparable rate of agreement for management decisions. However, evidence that these services provide similar or better outcomes than usual careis non-existent.

Data from economic evaluations to support store-and-forward telemedicine are poor because the studies provide an incomplete picture of costs. Rather than compare the total costs for each approach, they compare the costs of setting up and maintaining a telemedicine application to only some of the other health care costs for a given episode of care. Thus, the studies of telemedicine applications provide, at best, comparisons of only one component of averted costs to intervention costs and, at worst, report only intervention costs. Cost-effectiveness has yet to be demonstrated in this technology.

## Self-Monitoring/Testing

The number of services that can be delivered at home is expected to increase dramatically in the near future, partly because of the accelerating rate of technology development. Other forces influencing this trend are the growing population of older persons and their desire to remain at home instead of move to care-management facilities that have on-site staff. With these factors in mind, we now consider findings of the key questions pertaining to self-monitoring/testing.

An overall summary of programs and evidence is shown in Table 11. Each row represents a clinical activity for which at least one self-monitoring/testing telemedicine program exists, withthe order determined by the number of programs performing that activity. In the rightmost five columns are brief synopses of the evidence for the major analytic framework questions. If a cell is blank, it indicates that no studies assessing self-monitoring testing telemedicine in that specialty have been done.

Table 11. Summary of evidence for self-monitoring/testing telemedicine^a^ ^b^

Clinical Activity | Diagnosis/Management | Access | Outcomes | Satisfaction | Cost
Chronic disease management | Good agreement for assessment of skin wounds (II-B) | | | Patients satisfied with technologies for overall management of diabetes, cardiovascular disease, and pulmonary disease (II-B)
Physiological monitoring | Home spirometry equivalent to pulmonary lab spirometry for lung transplant patients (I-A) | Quicker access to care for acute cardiac symptoms (III) | Conflicting data on benefit of home HgbA1c monitoring (II(a)-B)
Post-hospital -- post-operative follow-up | | | Home exercise monitoring may be comparable to in-hospital program (II-B)
Home-health care | | Home monitoring for nursing management may improve outcomes (III) | Blood pressure readings and antihypertensive medication adherence improved; real-time video results in comparable medication adherence, knowledge of disease, and ability for self-care (I-A) | | Weak evidence real-time video may reduce costs (<3 of 5-B) and hypertension monitoring may be cost-effective (<3 of 5-B)
Nursing-home care
Specialist consults or 2nd opinion
Diagnostic-test interpretation

a Each row represents a clinical specialty for which at least one self-monitoring telemedicine program exists, with the order determined by the number of programs in that specialty.

b Blank table areas indicate that no studies assessing self-monitoring/testing telemedicine in that specialty have been done.

Self-monitoring/testing telemedicine is used less frequently than the other two types of telemedicine studied in this report. It is most commonly used for management of chronic diseases or specific conditions, such as heart disease, diabetes mellitus, or asthma. As with store-and-forward telemedicine, programs operate in many clinical domains, but with little evidence from peer-reviewed studies to support its use. The best evidence comes from studies with problematic designs, and even in those are as the benefit is inconsistent. Somestudies show it improves access, increases satisfaction with care delivered, and may be cost-effective.

### Key Question 1a. What are the characteristics of self-monitoring/testing telemedicine in terms of patients included, services provided, equipment used, and information transmitted?

As with all reported telemedicine programs, most self-monitoring/testing applications in the world are located in the United States (see Appendix F). These programs are scattered around the country, with a slightly higher concentration in California. Of the 21 programs identified, nine are in the Department of Veterans Affairs health system, 17 operate in medical centers, two are outside the United States and four are from independent agencies; nine provide home health services.

The most common situation where self-monitoring/testing is used is in managing a disease or specific condition, particularly heart disease, diabetes mellitus, or asthma. At the San Diego VA Medical Center, for example, on-call cardiologists can view electrocardiograms and monitor pacemakers from patients' homes.^ 28 ^ Patients use portable electrocardiogram machines to record and send cardiac-function data through the telephone for interpretation. Some patients also use electronic stethoscopes to record, monitor, and transmit heart and lung sounds. If the physician detects a problem, he/she then calls the patient and recommends a course of action. Such a telecommunication service is relatively inexpensive because it uses analog lines, or "plain old telephone service" (POTS).

The holistic support and care of at-risk patients are other important uses for self-monitoring/testing programs. Many older patients, terminally ill patients, and those with more than one chronic-disease risk factor are asked by professionals to assume increasing responsibility for their own care. With self-monitoring/testing telemedicine, patients can have periodic linkage with a professional nurse, physician, or another type of provider in a way that does not require the provider to spend travel time and does not over burden the patient with hosting responsibilities. Such contacts allow at-home monitoring by the patient or caregiver, which promotes joint responsibility for health maintenance. These contacts can be used for patient assessment, education, and counseling to prevent functional decline, nutritional emergencies, and medication lapses. The Kansas University Medical Center Home Health Pilot Project, for example, uses video-conferencing to interact with patients in their homes.^67, 40^ The nurse can assess the patient's skin condition, medication supply, insulinself-injection technique, and mental status. During a video conference call, the nurse can also reinforce instructions about how to check for skin breaks and prevent skin breakdown, and can do some planning with the patient and family to prevent anticipated problems in the home environment. In this way, a comprehensive case-management visit can be accomplished and reports can be distributed to various medical specialists and the primary care physician.

### Key Question 1b. Does self-monitoring/testing telemedicine result in comparable diagnosis and appropriateness of recommendations for management?

Since diagnosis is not usually the focus of self-monitoring/testing, few studies have assessed its diagnostic capabilities (see Evidence Table 3). Home spirometry is one diagnostic area that has been evaluated in more than one study. In a longitudinal, observational study of 18 lung-transplant patients, Finkelstein et al. found that the home pulmonary-function results were comparable to those of laboratory pulmonary-function results.^ 68 ^ Another small, uncontrolled study of moderate-to-severe asthmatic patients in Israel explored whether home spirometry measurements could lead to appropriate triage decisions.^ 69 ^ In this retrospective review of all home spirometry transmissions, the data were analyzed to detect that early signs of respiratory deterioration were correlated with the dispatch decision in only about half the patients. Thus, for purposes of urgent care, self-monitoring/testing in this population is not as reliable as oral communication, particularly for patients with severe asthma.

A study of telemedicine wound assessment,^ 57 ^ discussed above in the context of store-and-forward applications, can also be viewed as a self-monitoring/testing application. This study showed that skin-wound diagnosis is reliable when using digital photography. It also shows potential for teaching patients and family caregivers this mechanism of self-monitoring/testing.

### Key Question 1c. Does the availability of self-monitoring/testing telemedicine provide comparable access to care?

Although self-monitoring/testing is widely believed to affect access to care for patients, few studies have actually evaluated this. However, two studies do provide useful descriptions (see Evidence Table 4). In a large, case-series investigation in India that used telephone transmittal of electrocardiography data submitted by patients with acute cardiac symptoms,^ 70 ^ the average time from symptom onset to initiating a call to the physician was 30 minutes. The investigators compared this finding with an earlier study that reported this interval as an average of 40 minutes.^ 71 ^ Neither study described call times without telemedicine for comparison.

A qualitative study of home monitoring for nursing management^ 72 ^ attempted to interpret utilization and outcomes. The intervention was a visit in which patients at home used a two-way video phone, a blood pressure and pulse monitor, an electronic stethoscope, a call button, and an optional emergency-response system to report their condition to a nurse at a central station. All subjects (n = 12 disabled or chronically ill persons) had on-demand, face-to-face electronic access with the nurse; traditionally, a call from the patient had prompted an urgent (i.e., same day or within 2 hours) home visit from the nurse. However, this change was not actually measured in the study. The authors provided only case descriptions, and reported that eight subjects (67 percent) had more home care without added in-person visits and that four subjects (33 percent) avoided some days in a hospital or nursing home, or avoided clinic visits. The findings suggest that patients with certain types of conditions and living arrangements may benefit from self-monitoring/testing via a telemedicine technology. However, because it was uncontrolled, the study does not support the premise that improved access to care, or reduced utilization of more intensive services, was due to the telemedicine intervention.

### Key Question 2. What are the potential adverse effects of self-monitoring/testing telemedicine?

We found no studies that assessed the potential adverse effects of self-monitoring/testing applications. That is, no studies reported on technical problems or incomplete or inaccurate information nor whether the availability of self-monitoring/testing applications led to over-utilization or increased the cost of care.

### Key Question 3. Does self-monitoring/testing telemedicine result in comparable health outcomes?

We found seven studies that addressed health outcomes of disease-management in chronic disease populations, three assessing intermediate health outcomes and four assessing actual health outcomes (see Evidence Table 5). The most heavily studied area has been telemedicine-based home monitoring of blood glucose level by patients with diabetes who uploaded results for interpretation by their clinician. Among such patients, self-monitoring/testing is part of the daily routine. Other areas studied included hypertension management, videophones for patients with chronic diseases, and home exercise monitoring in cardiac rehabilitation.

We identified three randomized controlled trials that assessed the study population for improvement in the intermediate health outcomes of HgbA1c level in patients using upload of data from glucose monitoring machines compared with paper diaries assessed by the clinician at a periodic office visit. All of the studies were of short duration (no longer than a few months) and used relatively small numbers of patients. The largest study (n = 42), which also reported the most detail, showed that both the experimental and control groups improved, with no statistically significant difference between them, though the small sample size may have lacked statistical power to show significance for the difference which did occur infavor of the experimental group.^ 73 ^

Two other studies were smaller and reported their results in less detail. One study demonstrated a small magnitude but statistically significant benefit^ 74 ^ The other compared a home system for glycemic monitoring to a paper-diary system.^ 75 ^ Although it was a controlled trial, it was limited by incomplete reporting of data, including the magnitude of the difference between the experimental and control groups.

Another study of intermediate outcomes was a randomized controlled trial by Friedman etal. assessing the effect of a computer-controlled, automated telephone system versus usual office-based care on adherence and blood pressure control in older hypertensive patients (n = 267).^ 76 ^ Mean antihypertensive medication adherenceimproved 17.7 percent for telephone system users and 11.7 percent for controls (p = .03). Mean diastolic blood pressure decreased 5.2 mm Hg in users compared to a 0.8 mm Hg drop in controls (p = .02). There was also a positive relationship between medication adherence and blood pressure reduction. Although the improvements were modest, the quality of this study indicates that automated reporting is a valuable technique for reducing cardiac risk.

Four studies, including two controlled studies, measured actual health outcomes for home health telecare (Evidence Table 5). The largest and best designed was a randomized controlled trial where both the intervention and control groups were provided usual home health care but the intervention group also received a video system that allowed real-time remote interaction with the health system.^ 77 ^ Both groups had comparable compliance with medication regimen, knowledge about their disease, ability to move toward self-care, and scores on the 12-item Short-Form Health Survey (SF-12)™.

Two other studies described the use of videophones for patient communication with health care providers. In a study in Japan, 16 elderly patients who were provided with videophones were compared to 16 matched patients who used regular home health services.^ 78 ^ After 3 months, the videophone group significantly exceeded the control group in activities of daily living, communications, and social cognition, as measured with the Functional Independence Measure.^ 79 ^ The videophone intervention was a supplement to (not a substitute for) regular home health services. The second study,^ 72 ^ a qualitative report of 12 cases, was described earlier in the section on self-monitoring/testing and access to care.

In another study,^ 80 ^ a randomized trial of 20 patients, a home-exercise program with transtelephonic exercise monitoring and a hospital-based program improved cardiac function by a similar amount. However, the study had such low statistical power that it would not be likely to detectany difference between the two interventions in efficacy or in complications even if they existed.

### Key Question 4. Does self-monitoring/testing telemedicine result in comparable patient or provider satisfaction with care?

We found no studies that reported provider satisfaction in this study area.^81, 82^ cardiovascular disease,^ 83 ^ pulmonary disease,^ 84 ^ hypertension,^ 76 ^ and general chronic diseases (see Evidence Table 6). Three of these studies were randomized trials^76, 77, 82^ and three were case series with convenience samples.^81, 83, 84^ In the controlled studies, satisfaction was reported for the intervention groups, but not for the control groups. Thus, the evidence shows that self-monitoring/testing leads to patient satisfaction that is comparable to usual care methods.

### Key Question 5. Does self-monitoring/testing result in comparable costs of care? Is self-monitoring/testing telemedicine cost-effective?

Two papers reported cost data for self-monitoring/testing telemedicine services (see Evidence Table 2). The first paper^ 77 ^ reports a randomized comparison of home health care with video monitoring (including diagnostic capabilities as stethoscope and blood pressure cuff) to home care without video monitoring. Costs are not aggregated by these authors but left as three separate items (home health costs, inpatient costs, and all other healthcare costs). Total costs to the healthcare plan (excluding inpatient costs) were comparable in the two arms ($63 lessper patient for those with video monitoring). If the inpatient costs had been averaged across all patients in each of the two study arms, the total care costs would have been $916 lower in the intervention arm compared to the control arm. Thus the cost of the video-monitoring component was more than offset by other health care costs (such as outpatient visits and inpatient stays). The lower inpatient and outpatient costs for the intervention are very intriguing and suggest that cost-effectiveness analyses (using perhaps life years or other effectiveness measure) may demonstrate a substantial difference between these two interventions. No sensitivity analyses were performed and no attempt was made to estimate confidence intervals or conduct hypothesis tests for cost data. Patient's time on study was not reported. Additional analyses of these patients could have provided even greater information on the value of this technology.

This paper^ 72 ^ provided virtually no detail on assessed costs, which were based on estimates of care-intensity savings.

### Key Question 6. Does self-monitoring/testing result in comparable costs of care? Is self-monitoring/testing telemedicine cost-effective?

One study reported cost-effectiveness data. In a controlled trial of hypertension management,^ 76 ^ subjects randomized to the group receiving a weekly telephone call showed greater increases in medication adherence and greater decreases in mean diastolic blood pressure than the control group, who received usual care. The cost component of the economic evaluation was based on estimated costs of the system and not on actual patient experience. Few details of the cost estimate were provided and no sensitivity analyses were performed. Also, since no data on alternative regimens were provided, it is difficult to assess the economic impact of this intervention compared to other treatments or ways to improve compliance. Despiteits limitations, this study was the only example of a true cost-effectiveness study that we identified.

### Summary

Table 11 summarizes the research evidence for each question in our analytic framework for each type of self-monitoring/test activity occurring in the telemedicine programs described in the general literature. With the exception of remote hypertension and blood glucose management, the evidence for chronic disease management and holistic patient care using self-monitoring/testing is limited. This is largely due to a paucity of studies rather than to negative results (that is, it is a matter of "not proven" rather than "proven not").

## Clinician-Interactive Services

For this study area, the overarching question is, How well can telemedicine substitute for face-to-face clinical encounters, particularly non-consultative encounters such as visits by primarycare and specialist physicians? An overall summary of programs and evidence is shown in Table 12. Each row represents a clinical specialty for which at least one clinician-interactive telemedicine program exists, with the order determined by the number of programs in that specialty. In the rightmost five columns are brief synopses of the evidence for the major analytic framework questions. If a cell is blank, it indicates that no studies assessing clinician-interactive telemedicine in that specialty have been done.

Table 12. Summary of evidence for clinician-interactive telemedicine^a^ ^b^

Clinical Specialty | Diagnosis/Management | Access | Outcomes | Satisfaction | Cost
Cardiology | Chest pain assessment and decision to use thrombolytics improved (II-B) | Evening care limitations reduced by access to remote cardiologist (III)
Mental Health | Psychometric testing slightly inferior to in-person testing (II-C) | | | Providers satisfied with telecare but preferred in-person exam (III) | Cost benefits limited by study design (<2 of 6-C)
Dermatology | Agreement among in-person exams greater than between teledermatology and in-person exam (II-C) | | Requires same number of follow-up visits as in-person exam (II(b)-B) | Patient and physician attitudes toward system favorable (III) | Costs greater than in-person exam but might reverse with greater travel distance and greater consult volume (4 of 5-C)
Emergency/Triage | Emergency patient evaluation comparable to in-person exam (II-B) | | Remote emergency care has same outcomes as in-person care (I-A) | Emergency physicians and patients comfortable with system (II-B) | Cost benefits limited by study design (<1 of 5-C)
Neurology | Parkinson's Disease evaluation comparable to in-person exam (II-B) | | | Most Parkinson's Disease patients not scared by technology (III)
Orthopedics | | | | Patient and physician attitudes toward system favorable (III)
Pulmonary Care | Pulmonary history and exam comparable to in-patient exam (II-B)
Internal Medicine | | | | Primary care physicians as satisfied with care as those not having telemedicine (III) | Cost benefits limited by study design (<3 of 6-C)
Oncology/Hematology | | | | Cancer patients satisfied with remote system but preferred in-person care (III)
General Surgery
Gastroenterology
Ophthalmology | Good agreement with in-person exam for HIV disease, less for diabetes mellitus (II-C) | | | Patients satisfied with care (III)
Obstetrics/Gynecology
Nephrology
Infectious Disease
Rheumatology
Nutrition
Primary Care
Otolaryngology | Remote exam comparable to in-person exam (II-B) | | | Patients satisfied with care (III) | Cost benefits limited by study design (<4 of 6-C)
Home Health Nurse
Speech Pathology | | | | Vascular surgeons satisfied with telecare (III)
Dentistry | Dental evaluation comparable to in-person exam (III-B)
Urology | Urology consults altered treatment in half of cases (III-C) | | Remote mentoring of procedures had no increase in complications or time of operation (III-B)
Endocrinology
Specialty Surgery | | Remote consultation improved access to neurosurgical care (II) | Remote consultation has fewer adverse events during transfer (III-B)
Geriatrics
Rehab Nursing
Burn Treatment
Nuclear Medicine
Podiatry
Plastic Surgery
Physical Therapy
Rehabilitation Counseling
Oral/Maxillofacial Surgery
Pharmacy
Nurse Clinician
Gerontology
Electrodiagnosis
Dialysis
Diabetic Instruction
Audiology
Pain Management
Other

a Each row represents a clinical specialty for which at least one self-monitoring telemedicine program exists, with the order determined by the number of programs in that specialty.

b Blank table areas indicate that no studies assessing self-monitoring/testing telemedicine in that specialty have been done.

As with the two other study areas, while there are programs that operate in many clinical domains, studies assessing the efficacy are lacking in most of them. Furthermore, for many settings where studies have been done, the evidence for efficacy is of insufficient quality to judge how well clinician-interactive telemedicine works. Clinician-interactive telemedicine is used in more heterogeneous clinical specialties than store-and-forward. Unlike those for store-and-forward telemedicine, several studies showed interactive teledermatology to be inferior to in-person consultation in making diagnostic and appropriate management decisions, though many of these were done with older technology, unlike the store-and-forward studies. In several other clinical specialties, clinician-interactive telemedicine shows comparable diagnostic accuracy, and inemergency medicine one randomized controlled trial showed it to have comparable health outcomes. Some studies demonstrate improved access to care, patient and provider satisfaction, and reduced costs of care, though most have problematic designs.

### Key Question 1a. Which clinical services are or might be provided by clinician-interactive telemedicine?

We identified 625 activities of clinician-interactive telemedicine. Table 13 lists the clinical specialties while Table 14 lists the clinical activities. A wide variety of clinical services are being provided via clinician-interactive telemedicine.

Table 13. Clinical specialties of clinician-interactive telemedicine programs

Clinical specialty | Number of programs
Cardiology | 67
Mental Health | 66
Dermatology | 51
Radiology | 51
Emergency/Triage | 41
Neurology | 36
Orthopedics | 29
Pulmonary Care | 27
Pediatrics | 24
Internal Medicine | 22
Pathology | 18
Oncology/Hematology | 18
General Surgery | 15
Gastroenterology | 13
Ophthalmology | 12
Obstetrics/Gynecology | 11
Nephrology | 11
Infectious Disease | 11
Rheumatology | 10
Nutrition | 7
Primary Care | 7
Otolaryngology | 6
Home Health Nurse | 5
Speech Pathology | 5
Dentistry | 5
Urology | 4
Endocrinology | 4
Specialty Surgery | 3
Geriatrics | 3
Rehab Nursing | 2
Burn Treatment | 2
Nuclear Medicine | 2
Pediatric Cardiology | 2
Podiatry | 2
Plastic Surgery | 2
Physical Therapy | 2
Rehabilitation Counseling | 2
Oral/Maxillofacial Surgery | 1
Pharmacy | 1
Nurse Clinician | 1
Neonatology | 1
Gerontology | 1
Electrodiagnosis | 1
Dialysis | 1
Diabetic Instruction | 1
Audiology | 1
Pain Management | 1
Other | 1

Table 14. Clinical activities of clinician-interactive telemedicine programs

Clinical activity | Number of programs
Specialist Consults or Second Opinions | 166
Chronic Disease Management | 93
Diagnostic Test Interpretation | 91
Post-Hospital/Post-Operative Follow up | 70
Emergency Room/Triage | 67
Specialist Visits | 59
Home Health | 20
Physiological Monitoring | 19
Nursing Home Care | 8
Primary Care | 7
Psychiatric Exams | 4
Patient Education | 4
Legal/Judicial Proceedings | 4
Nutrition Consultation | 3
Rehabilitation | 2
Medical Supervision | 1
Initial Assessment/Evaluation | 1
Hospice Care | 1
Trauma | 1
Grand Rounds | 1
Social Service | 1
Medication Management | 1

### Key Question 1b. Does clinician-interactive telemedicine result in comparable diagnosis and appropriateness of recommendations for management?

We assessed the evidence for the diagnostic and/or management decision capability of telemedicine systems on a per-specialty basis. The most represented specialty was dermatology, with no other specialties having more than two studies.

Six teledermatology studies that assessed diagnostic and/or management decisionsused interactive videoconferencing (see Evidence Table 7). In the study with the best methodologic quality,^ 85 ^ diagnostic agreement for interactive teledermatology versus in-person encounters was significantly lower than in-person versus in-person agreement. This is incontrast to the store-and-forward study with the best methodology,^ 48 ^ which showed comparable agreement for teledermatology versus in-person to in-person versus in-person. There are several possible reasons for the poorer performance of interactive teledermatology. The store-and-forward study used 24-bit color digital images, whereas the interactive study used standard television. Another possibility is that store-and-forward telemedicine is more effective than interactive telemedicine, a non-intuitive hypothesis that would need further explicit investigation. A third possibility is that the patient populations differed between the two studies. The teleconferencing study selected patients who had a "skin problem" as opposed to those referred for dermatology consult. It would require further study to determine whether this bias was a factor in the diagnostic performance of the technology.

The remaining studies had more serious methodologic limitations. Three used the same dermatologist for the teledermatology and in-person consultation.^86-88^ Two studies assessing the agreement of detecting malignancies had insufficient sample size to estimate the false-negative rate of the teledermatology examination, and did not employ a gold standard (e.g., biopsy) to determine whether cancer was present.^89, 90^ Although most of the other teledermatology studies had adequate patient sample sizes, all of the studies were also limited by the small number of dermatologists taking part. Only four listed the number of participating dermatologists, and none of these had more than six dermatologists.

Thirteen studies assessed diagnostic accuracy in a variety of other clinical domains in populations relevant to Medicare (see Evidence Table 8). All of these studies either lacked a definitive gold standard or did not assess inter-observer agreement in addition to telemedicine versus in-person agreement. Only two of them evaluated management decisions. Most had relatively small numbers of patients and, especially, clinicians. The following applications are supported by weak evidence for diagnostic accuracy via telemedicine:

- Chest pain assessment in the emergency department^91, 92^
- Availability of teleradiology in the emergency department^93, 94^
- Parkinson's Disease assessment^ 95 ^
- Ophthalmology services for some patients (e.g., general eye and HIV patients) but not others (e.g., diabetics)^41, 56^
- Pulmonary history and physical assessment^ 96 ^
- Dental evaluation^ 97 ^
- Otolaryngology assessment^ 98 ^
- Psychometric testing^ 99 ^
- Urology assessment^ 100 ^

Two studies focused on the effect of telemedicine on management decisions. In one of these, a remote cardiologist reviewed the history and electrocardiograms of patients with suspected myocardial infarction, then advised a senior house officer whether or not touse thrombolytic therapy. Eight patients who would have received thrombolytic therapy did not, and four who would not have, did.^ 91 ^ In the other study, remote urologists assessed 14 real and 18 simulated patients with urolithiasis and recommended medical or surgical intervention.^ 100 ^ The urologistin the academic center using telemedicine advised a change in plan of care for half of the real and 17 percent of the simulated patients of the local urologist. In both studies, there commendations of the remote specialist was the gold standard, and there was no independent verification of their assessments nor any follow-up to determine whether their recommendations proved beneficial to the affected patients.

### Key Question 1c. Does the availability of clinician-interactive telemedicine provide comparable access to care?

As noted above, some teleconsultations (CPT codes 99241-99245, 99251-99255, 99261-99263, and 99271-99275) in rural HPSAs have been covered under Medicare since 1998, but the impact of this coverage is not yet clear. One reason for this uncertainty is that no formal effort has been made to measure the impact of this coverage on access.

Eight studies addressed patient access to services in three medical domains and one nursing domain (see Evidence Table 9). Three measured access to acute neurosurgical care,^101-103^ two to medical-surgical consultation,^104, 105^ two to cardiac care,^91, 106^ and one to ultrasonography.^ 107 ^

All of these studies showed improved access to care by allowing more local care for patients. In two observational, controlled studies with similar sample sizesand similar telemedicine interventions that transmitted image and other data to neurosurgeons for evaluation and triage assistance, local care (i.e., fewer distant-care transfers) increased by 33 percent^ 103 ^ and 21 percent^ 102 ^ respectively. In a comparison study, telemedicine increased the availability of ultrasound service in a small, remote town by 36 percent.^ 107 ^ None of these studies used randomly selected or randomly assigned samples, none specified the sampling inclusion criteria, and almost none supplied details about the subjects' medical conditions. Thus, the improvements could possibly be attributed to differences in the samples rather than to the intervention.

Other findings regarding access were based on descriptive studies. Bailes^ 101 ^ found that in 100 consecutive contacts with neurosurgeons for assistance with emergency triage decisions, there were fewer transfers for spinal injury (33 percent), stroke (25 percent), intra-cranial hemorrhage (23 percent), suspected tumor (21 percent), and various other conditions (62 percent). The implied comparison was the pre-telemedicine situation when all patients with these conditions were transported to a distant hospital. Since the study did not use a matched sample, and few details were provided about the triage decisions or decision-makers, the evidence is weak.

Several studies utilized poor measures or data-collection processes to determine access change. In two,^104, 106^ improved geographic access was measured with physician ratings of the potential for transfer, rather than actual transfer. In another,^ 105 ^ primary care military physicians entered patient-evacuation impressions in a log and were later interviewed about changes in their initial plans, but no steps were taken to make the data-gathering process more objective.

The other type of finding regarding access to care with telemedicine was quicker service, and four studies measured access time. A study in Hong Kong^ 102 ^ showed that telemedicine reduced the mean transport time required for emergency care from 80 to 72 minutes, but the difference was not significant. Bailes^ 101 ^ reported that direct admission from helicopter to operating room was achieved for 20 percent of the experimental subjects (n = 25) and for none of the control subjects, when examination and image data could be sent ahead electronically. In another example of access based on timing, Srikanthan^ 91 ^ reduced the evening care limitations by offering after-hours access to a cardiologist, who could review transmitted data at home. In the sample of 112 patients, 15 percent received "more appropriate" treatment after hours. Although these studies show modest positive results, they have several design and reporting limitations, including the lack of randomized samples, unreported sample inclusion and exclusion criteria, unreported reliability and validity, and unreported significance. One study^ 107 ^ is also limited by considerable missing data (39 percent in the control group, 14 percent in the experimental group).

### Key Question 2. What are the potential adverse effects of clinician-interactive telemedicine?

As with the other study areas, we found few studies that explicitly assessed the potential adverse effects of clinician-interactive applications. That is, no studies reported on technical problems or incomplete or in accurate information or on whether the availability of clinician-interactive applications led to over-utilization or increased cost of care. The adverse effects of increased burden on the referring clinician reported for store-and-forward telemedicine are likely to apply here as well.

### Key Question 3. Does clinician-interactive telemedicine result in comparable health outcomes?

We identified seven articles that assessed health or clinical outcomes, two of which appeared to be reports of the same study. There were thus six studies, including two randomized controlled trials, concerned with patient outcomes in clinician-interactive services (see Evidence Table 10). The studies cover anumber of domains. It is interesting to note that few studies of outcomes were in the subject areas most intensively studied in the first question of the analytic framework -- accurate diagnosis and management plans.

One randomized trial assessed outcomes in patients entering an emergency department who were randomized to in-person or telemedicine care.^ 108 ^ There were no differences in the need for additional follow-up care or return to the emergency department, showing that telemedicine was as effective as regular care in this setting.

Another randomized controlled trial assessed "clinicaloutcome," which was defined as the need to have a follow-up appointment with a hospital-based specialist.^ 109 ^ Interactive teledermatology consultation (46 percent) was found to have the same rate of need for follow-up care as in-person consultation (45 percent). No statistical analysis of the differences was performed.

The remaining studies lacked matched control groups^102, 110-112^ and had a very small sample size, with the resultant lack of statistical power.^ 111 ^ Consequently, there is little evidence that telemedicine for clinician-interactive services improves or does not improve the outcomes of clinical care.

### Key Question 4. Does clinician-interactive telemedicine result in comparable patient or clinician satisfaction with care?

Eleven studies reported on patient satisfaction (see Evidence Table 11). Ten studies were found to report on provider satisfaction, eight of which also reported on physician/provider satisfaction (see Evidence Table 12).

Nineteen studies reported on patient satisfaction with clinician-interactive services. Overall, patients, parents of patients, and families of patients were satisfied with the services. While the quality of these studies was poor, there was no contrary evidence in the literature. All 19 studies were based on convenience samples, and 13 were uncontrolled. In a randomized trial,^ 108 ^ there were no significant differences between the telemedicine and control groups on positive patient-physician interaction, patient-nurse interaction, or overall satisfaction rate. Patients in both groups were generally satisfied with their care. Of the other studies that included control groups, four had patients serving as their own controls, undergoing both teleconsultations and face-to-face consultations.^88, 113, 114^ One of these^ 113 ^ reported on a videoconferencing system for oncology patients living a substantial distance from their outpatient clinic site. Those same patients served as their own controls at a later, face-to-face visit. While the authors reported that the patients were generally equally satisfied, the patients stated that they were more comfortable saying what they needed to say in-person. In addition, after the in-person consultation, patients were reported as less inclined to want to use the teleconsulting service.

Of the 10 provider satisfaction studies, nine were case series with convenience samples and no control groups. Sample sizes ranged from one referring physician and one consultant^ 115 ^ to five dermatologists and 27 referring physicians.^ 88 ^ In several studies, the sample size was unspecified.^66, 116-118^ Provider satisfaction was determined through the use of printed questionnaires, interviews, and focus groups, with no one method predominating. No study reported reliability or validity information on any of the data-collection tools.

In general, providers were satisfied with their teleconsultation experiences. The providers felt, overall, that videoconferencing provided them with enough information of good quality to constitute a satisfactory alternative to face-to-face consultations. Studies in the psychiatry domain found that participating physicians expressed overall satisfaction with the technology, but, given a preference, would chose face-to-face assessments. Despite the limitations of the evidence usedto demonstrate provider satisfaction with telemedicine, there was no conflicting evidence in the literature indicating any provider dissatisfaction.

### Key Question 5. Does clinician-interactive telemedicine result in comparable costs of care?

In general, there is little high-quality evidence that applications thatsubstitute interactive telemedicine for face-to-face services result in comparable total costs or provide a cost-effective alternative to usual care. Twelve studies reported economic evaluations in clinician-interactive services. The design characteristics, quality, and results of these studies are described in detail in Evidence Table 2.

These studies fall into two categories: patient visit replacement and decision support. In visit replacement, the telemedicine application is designed to avoid an office visit by transmitting information from the patient's location to the physician's location. Decision support involves transmission of information designed to implement an immediate decision on patient care (typically whether or not the patient needs emergency transport from a regional medical center to a central medical center such a tertiary care center).

Nine studies assessed visit replacement. The medical specialties included otolaryngology,^ 119 ^ dermatology,^120, 61, 62, 109, 121^ psychiatry,^ 116 ^ oncology,^ 122 ^ and general medicine^ 72 ^. Three studies appear to come from the same randomized controlled trial of real-timedermatology visits conducted in Northern Ireland.^61, 62, 109^ One study reports that the total societal costs for a real-time teledermatology visit are greater than for a conventional in-person consultation, but greater volume and other efficiencies might reverse this difference. For the rest of the papers, the typical study in this group compared the cost of the set-up and maintenance of a telemedicine application to the costs of transporting either the patients from a remote site to a central site or the specialists from a central site to a remote site. The number of patient visits required to break even (travel costs saved would equal total costs of the telemedicine application) was usually estimated. All of these studies concluded that, given some adequate volume of patients, the telemedicine application would cost less than transporting patients or physicians. A tenth study by Cameron^ 123 ^ presented a general simulation-model approach to economic evaluations and used a video teleconsultation service as an example.

These studies leave important questions unanswered. They do not report comparisons of the total costs of an episode of care or even many components of episodes of care other than transportation of patients for emergency care. They also ignore potential adverse events or necessary follow-up visits. Studies that provide data to answer these questions will allow meaningful assessment of costs of care and cost-effectiveness of telemedicine applications.

Decision support was described in six studies covering neurology and neurosurgery,^124, 125^ radiology,^103, 126^ and emergency medicine.^101,127^ In mostcases, the decision was whether or not a patient should be transported from a remote site to a central site. Based on reviews of patients who received telemedicine support (up to 200 patients), other averted or induced costs were ignored. These studies report how many patient transports need to be averted to offset the costs of the telemedicine program. They pose similar problems to those for the visit replacement category above, and several have potential biases. As with the previous category, the only costs considered beyond the costs of the telemedicine application were patient transport costs.

### Key Question 6. Is clinician-interactive telemedicine cost-effective?

We identified no studies of the marginal cost-effectiveness of clinician-interactive telemedicine.

### Summary

Table 12 summarizes potential services, existing programs, and documented effectiveness for clinician-interactive services telemedicine. Each row represents a clinical specialty for which at least one clinician-interactive telemedicine program exists, with the order determined by the number of programs in that specialty.

As can be seen, there tends to be good correlation between the existence of programs in given specialties and studies assessing the evidence for those specialties. Unfortunately, however, the methodologic quality of those studies makes the beneficial evidence weak at best. For several services, there are a number of Class II-B and III-B studies for some key questions, indicating that telemedicine technologies show promise in methodologically less rigorous studies. The table also shows that diagnosis and management studies tend to be of higher quality than outcomes, satisfaction, or cost studies.