# Methodology

This chapter describes the methods we used to identify and describe existing telemedicine programs in the three study areas and to summarize the scientific evidence for effectiveness and cost. Separate to this analysis, we performed an assessment of the applicability of procedure codes to telemedicine, which is reported in Appendix A.

## Literature Search

We searched the general literature for information about ongoing telemedicine programs, activities, and services throughout the world. This comprehensive search focused on obtaining journal articles and reports pertaining to the three study areas. We searched for peer-reviewed and non-peer-reviewed literature from several bibliographic databases. We identified programs from the following.

### Electronic bibliographic databases

A search string designed to find any publications about telemedicine was used to search MEDLINE, EMBASE, CINAHL, and HealthSTAR

(Appendix B). The search strategy initially resulted in 3,422 citations, and monthly updates of the same strategy through January 2000 yielded 171 additional citations.

### Published reports

We searched through telemedicine reports and compilations such as the "Quebec Report" from the Conseil d'Evaluation des Technologies de la Sante du Quebec,^ 24 ^ the Telemedicine Strategic Healthcare Group report^ 25 ^ the International Society for Telemedicine Conference 1999 summary,^ 26 ^ the Australian National Telehealth Committee reports,^ 27 ^ and the Telemedicine Sourcebook 1998. ^ 28 ^ These reports provided valuable perspectives on a wide variety of telehealth projects. We also assessed three systematic reviews (different in scope from this report) from theInternational Network of Agencies for Health Technology (INHATA),^ 29 ^ the Cochrane Database of Systematic Reviews,^ 30 ^ and the Agencia d'Avaluacio de Technologia Medica.^ 31 ^

### Internet program information

We also searched the Internet for telemedicine program information. Examples of sources obtained through this approach are the Telemedicine Information Exchange (http://tie.telemed.org), the Canadian Initiatives on Networking Clearing House (http://strategis.ic.gc.ca), and the Midwest Rural Telemedicine Consortium (http://www.mrtc-iowa.org).

### Reference lists

We identified 178 additional articles from the reference lists of included reports and articles.

### Contacts with experts

We contacted known telemedicine experts to find additional resources to identify and describe telemedicine programs. Through one such contact, the project purchased the Association of Telemedicine Service Providers' database^ 4 ^ of self-reported information about current telemedicine programs in 1997 and 1998. The information in this database was obtained by surveying administrators of these telemedicine programs. These administrators (n = 551) were identified by reviewing vendor press releases, notices of grant awards, telemedicine literature, and ATSP membership records. New and prior respondents were surveyed, and respondents received a complimentary copy of the 1998 report for participating.^ 32 ^ The electronic version of this database has been updated by an annual survey and by interim telephone validation of information gleaned from key informants, the literature, and the Internet. A total of 141 programs were described in the 1998 ATSP database. (From 1998 report. 1999 report not yet available.)

## Selection of Abstracts and Full-Text Articles

The results of the literature search and selection of articles for inclusion are shown in Table 2. Two teams of two reviewers (WRH and SES, PKP and JAW) conducted independent screening reviews of all citation titles and abstracts (if available) obtained from indexed and non-indexed citation acquisition. The reviewers read citation titles and abstracts (or titles-only if the abstract was not available) to make inclusion decisions for subsequent full-article review. The criterion for inclusion in the general-literature review was that the article described an activity in at least one of the telemedicine study areas: store-and-forward, self-monitoring/testing, or clinician-interactive services. The inclusion criteria for the systematic review of peer-reviewed literature were that the study be relevant to at least one of the three study areas; that it address at least one key question in the analytic framework for that study area; and that it contain reported results (i.e., "data"). Exclusion criteria for articles in the systematic review were that the study population was not relevant to the Medicare population (i.e., children or non-pregnant adults) or that the service did not require face-to-face encounters (i.e., radiology or pathology diagnosis). For the store-and-forward study area, we included studies that used store-and-forward techniques as well as studies that used systems that could be easily adaptable to store-and-forward. We excluded reports of telephone care programs and equivalent programs that used electronic mail instead of the telephone. We also excluded studies of services that provided medical advice directly to the public.

Table 2. Results of literature search and abstract review

Action | Results
Initial search strategy conducted^a^
Initial search yield of citations Monthly update 1 Monthly update 2 Monthly update 3 Monthly update 4 ^b^ Subtotal first set of citations (initial search + monthly updates) Total exclusions from first set of abstract reviews ^c^ Total abstract inclusions from first set of citations | 3,422 + 62 +49 + 60 + 73 3, 666 −2,960 706
First set of articles pulled and reviewed
First set of articles reviewed for specific general literature and systematic review Excluded from further review of general literature articles Excluded from further review of systematic literature articles Total articles from first set of citations | 706 −135 −34 537
Review of articles and identification of additional source materials General Review of Literature
Subtotal for full general literature review (2^nd^ review) (initial search + monthly updates) Additional articles identified and reviewed from other sources Total full articles included for general literature review | 426 + 95 521
Systematic Evidence Review
Subtotal for full systematic review (2^nd^ review) (initial search + monthly updates) Additional articles identified and reviewed from other sources Total full articles included for systematic literature review Total full articles included for both literature review tasks | 111 + 83 194 715

a See Appendix B for listing of search strategies.

b Monthly updates on search strategy conducted through01/31/2000.

c Exclusions were made from a phase one screening review of abstracts.

Reviewers rated the titles and abstracts for both the general-literature and the systematic review simultaneously. Reliability of the inclusion decisions was assessed by noting the percent of agreement for inclusion between two independent reviewers. For one pair of reviewers (WRH:SES; n=1,480 citations) there was 77.3 percent agreement for the inventory of programs and 91.6 percent agreement for the systematic review. For the other pair (PKP:JAW; n=1,508 citations) there was 71.1 percent agreement for the inventory of programs and 87.0 percent agreement for the systematic review. A third reviewer (MRG), who was blinded to previous reviewers' results, made "tiebreaker" decisions for citations about which the pairs disagreed. We retrieved the full-text articles for citations selected for possible inclusion in either the inventory or the systematic review.

The phase-one review yielded 426 citations judged potentially relevant for the inventory-development task. It also yielded 111 citations judged potentially relevant for the evidence-review task. During the course of the study we identified more articles from both reference lists of studies and suggestions from experts which were included in the analysis.

## Data Abstraction

### Inventory of Programs

We developed an inventory of telemedicine programs worldwide. A program was defined as a set of actions within a location where telemedicine was centered and organized. Within each program were one or more activities (e.g., one program might have activities in teleradiology and teledermatology). The inventory of programs was constructed using the ATSP database^ 4 ^, articles from the general-literature review, and other sources of information as listed above. We used information only from written descriptions of programs in print publications or on Web sites; we did not attempt to contact programs personally. For each article, we attempted to obtain information about nine characteristics of the program: geographic location; clinical applications; payment sources and methods; quality standards; data systems for tracking utilization; telecommunication links and equipment; system costs; utilization; and other issues. We also tried to determine whether a program used store-and-forward telemedicine, either purely or in combination with interactive telemedicine.

The abstracted data of programs were entered intoa relational database for aggregation and interpretation. We used many of the same database fields and enumerated values within fields as the ATSP database, such as clinical specialty and clinical activity.^ 4 ^ The database was constructed using Microsoft Access^TM^ software and initially populated with the ATSP 1998 data. Information about other domestic and international programs identified in the literature review was added as it was acquired. Appendix C lists the variables in this database.

### Systematic Review

Included articles were categorized by the key question(s) they addressed, by WRH and SGS (using consensus to break ties), and distributed to members of the research team. For each key question, data from each study were abstracted by a single reviewer, using paper or electronic abstraction forms, and entered into an electronic database. For all studies, we recorded the setting (e.g., academic center, community hospital, government hospital), clinical activities, type of equipment used, year(s) in which data were collected, features of the design of the study (e.g., controlled trial, case series), aspects of recruitment (volunteers, invitation, consecutive or non-consecutive patients), type of control (if applicable), and measures used to assess the effectiveness of the intervention. Additional information was abstracted depending on the key question that was addressed. For studies of diagnostic performance, we recorded the test used as the reference standard and the reported sensitivity and specificity of the telemedicine diagnosis. Additional variables that were abstracted for studies of the economic impact of telemedicine activities included the type of economic study, types of comparisons, data sources, cost unit, discount rate, sensitivity analysis parameters, program expansion capability, and generalizability of the program.

## Assessment of Study Quality

We critically appraised the included studies for each study area and key question and discussed the strengths and limitations of the most important studies at weekly meetings of the research team. Appendix D presents a detailed rationale for the appraisal of study characteristics related to quality. Studies that examined the effect of telemedicine activities on clinical outcomes, patient satisfaction, or access to care were rated for quality according to the scale shown in Table 3.^ 33 ^ The optimal design for studies of a diagnostic test is different from the optimal design for studies of therapies. For this reason, we used a separate scale to rate the quality of studies that compared the accuracy of "telediagnosis" to diagnosis made in conventional clinical encounters (Table 4). We also abstracted features of the study design that were likely to be associated with bias in studies of diagnostic test performance.^34, 35^

Table 3. Classification of evidence for studies of therapy and monitoring

Strength of evidence
Study Class | Characteristic
I II III | Properly designed random controlled trials Random controlled trials that contain design flaws preventing specification of Class I Properly designed trials with control groups not randomized Multi-center or population-based longitudinal (cohort) study Case control studies Descriptive studies (uncontrolled case series) Clinical experience Expert opinion Case reports
Direction of effect
Study Class | Characteristic
A B C D | Strong positive effect Weak positive effect Conflicting evidence for effect Negative effect (evidence that the technology is inferior or ineffective)

Table 4. Classification of evidence for diagnostic studies

Evidence of effect
Study Class | Characteristic
I II III | Case series of consecutive patients from relevant population of individuals who would use telemedicine; using an objective gold standard with blinded interpretation of results; with inter-observer analysis Case series of patients from relevant population of individuals who would use telemedicine; using an objective gold standard Case series not from relevant population or not using appropriate methodology for diagnostic test evaluation

We also applied the following additional criteria to studies addressing access to care, patient satisfaction, and economic analyses.

### Access to Care

In appraising studies of access to care, we employed the Institute of Medicine^ 7 ^ (IOM) model of access to care, which incorporates four types of indicators: barriers (structural, financial, and personal); utilization; mediators (treatment effectiveness, provider quality, and patient adherence); and outcomes, including health status (e.g., mortality, well-being, or functionality) and equity of services among various populations. The IOM strongly recommended that studies of access to care measure both utilization and outcomes.

Our preliminary review of the telemedicine studies that addressed access showed that the majority relied on utilization indicators alone. A few used indicators of reduced barriers to care. Most studies measured access as 1) increased opportunity to obtain a service locally, and 2) reduced amount of time for seeking and/or obtaining care.

### Satisfaction Studies

Forty-five studies were identified by two reviewers (WRH and SES) as containing data on patient and/or provider satisfaction. These studies were divided into three categories: 1) studies dealing with patient satisfaction; 2) studies concerning provider satisfaction; and 3) studies that addressed both patient and provider satisfaction.

After examining the articles on satisfaction, we found that there was insufficient information in 13 studies to evaluate the strength of the evidence presented. For example, there was either no description of the sample or sample size, no description about how satisfaction information was collected, or no description how the data were analyzed. However, these papers did contain reports of patient and/or provider satisfaction that could be considered anecdotal, and may lend support to the general sense of the levels of satisfaction among patients and providers. Eleven of the studies were of various clinician-interactive services; one involved store-and-forward telemedicine and one was about self-monitoring/testing.

### Economic Analyses

The economic evaluation of the telemedicine applications from the literature review included both cost studies and cost-consequence studies. Economic evaluation is a more encompassing term than cost-effectiveness analysis. The term cost-effectiveness analysis refers to a particular class of economic assessments in which costs are compared to measures of effectiveness (such as life-years). Economic assessments encompass other study designs, including program-cost analyses and cost-of-illness studies. Program-cost analyses review only the cost of implementation and maintenance of a particular application. The other designs (including cost-effectiveness studies) are cost-consequence studies, which compare the costs to other consequences, including other economic consequences (as the costs averted by the application), technical consequences (as images of the same quality), or health outcomes (as length of stay or life-years).

Evidence Table 2 summarizes whether costs, charges, or both were used for a given study. Since the literature was limited, studies were not excluded based on reporting costs versus charges. Perspective and study design were summarized for studies evaluated based on how they were described in the articles. We excluded economic evaluations of applications for special populations (such aspediatric echocardiography) that have little bearing on a Medicare population. We also excluded economic analyses of telemedicine applications in prisons because the costs of transporting prisoners are also not relevant to a Medicare population. Finally, we excluded reports that claimed to report program costs but which had incomplete data or only a single summary cost, such as only the total cost to set up a telemedicine application.

To appraise economic evaluations, we applied six principles (Table 5) that were advanced in a previous review of the quality of published cost-effectiveness analyses.^ 36 ^ These principles provide a straightforward way of assessing the quality of economic evaluations, and are consistent with the guidelines for conducting economic evaluations outlined by the Panel on Cost-effectiveness convened by the U.S. Public Health service in 1993.^ 37 ^

Table 5. Summary of six principles for economic evaluations^36^

Principle | Description
Perspective stated Benefit described Costs included Discounting included Sensitivity analyses Cost-effectiveness ratios stated | Whose costs and consequences are considered? What are non-economic consequences of program? Describe intervention costs, morbidity or side effect costs, averted costs and induced costs? Are future costs and consequences adjusted for timing? For values that are uncertain (e.g. assumed), are analyses performed using alternative values? Are alternatives compared in a way that allows decisions on prioritization to be made?

## Data Synthesis and Identification of Information Gaps

We report our data synthesis in a summary that represents the state of knowledge for telemedicine in practice. For the synthesis, we used an approach that incorporates the types of data described above: 1) current telemedicine programs and activities in use by health care providers, as found in the literature; and 2) evidence found in a systematic review of telemedicine research. After first describing the clinical programs and research evidence, we present the interface of these elements on summary tables for each study area.

Results of the systematic review are presented in the evidence tables. The reviewer for each key question constructed separate evidence tables for each of the three study areas. In general, the evidence tables include author/date, key research question(s), study design/level, population, sample/selection, measures, results, quality rating, and limitations.

For each study area, we constructed a summary table of activities and the strength of the evidence for each link in the analytic framework. The summary tables identify telemedicine research gaps in two ways. First, the tables display procedures that are currently being delivered or could be delivered by telemedicine. Second, for those procedures or services that have evidence, the summary tables show which analytic framework links are supported by evidence, and which ones are not supported by evidence (or have not been examined in published studies). We also interpret our synthesis, and discuss the limitations of our approach to this evaluation.

We also developed recommendations for research to address telemedicine knowledge gaps. To match these gaps with the capabilities of specific research methods, we classified the telemedicine services according to the type of evidence that would be needed to determine whether the specific goals of covering such services had been met. We emphasized the relationship between the type and level of evidence found in the systematic review of effectiveness, the capabilities of HCFA's Medicare Statistical System to address the research question, and the costs and types of studies that might be done to address the gaps in knowledge in this growing field of research.