# Appendix G. Task Order Personnel

- Principal Investigator:
- William R. Hersh, MD
- Associate Professor and Chief
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- OHSU EPC Director:
- Mark Helfand, MD, MPH
- Associate Professor of Internal Medicine and Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- OHSU EPC Administrator:
- Kathryn Pyle Krages, AMLS, MA
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Research Coordinator:
- James A. Wallace
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Co-Investigator:
- Merwyn R. Greenlick, PhD
- Professor and Chair
- Department of Public Health and Preventive Medicine
- Oregon Health Sciences University
- Portland, OR

- Co-Investigator:
- Patricia K. Patterson, RN, PhD
- Assistant Professor of Nursing and Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Co-Investigator/Statistician:
- Dale F. Kraemer, PhD
- Assistant Professor
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Statistician:
- Benjamin K.S. Chan, MS
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Systems Analyst:
- Richard C. Wagner
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Librarian:
- Patty Davies, MS
- Oregon Health Sciences University Library
- Portland, OR

- Research Assistant:
- Gregory M. Eilers
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Graduate Research Assistant:
- Susan E. Shapiro, MSN, RN
- School of Nursing
- Oregon Health Sciences University
- Portland, OR

- Graduate Student Assistant:
- Manish K. Parehji
- Division of Medical Informatics & Outcomes Research
- Oregon Health Sciences University
- Portland, OR

- Technical Writer/Editor:
- Gary Miranda, MA
- Portland, OR

- Consultant:
- Frederick E. Richards, MEd
- Oregon Medical Professional Review Organization
- Portland, OR