# Appendix F. Self-Monitoring/Testing Programs

Self-monitoring/testing programs

Program Name | City | ST | Source | Activity | Specialty | Data Provided | Bandwidth | Tcom Svc. | Tcom Medium
Long Beach VA Medical Center | Long Beach | CA | Rosenthal, 1997^ 1 ^ | Chronic disease management, physiological monitoring | Cardiology | pacemaker monitoring | POTS (up to 54 kbps) | Standard phone service (POTS) | Terrestrial/phone lines
Kaiser Tele-Home Health | Sacramento | CA | Anonymous,1998,^ 2 ^ Johnston,1997^ 3 ^ | Chronic disease management, home health, physiological monitoring, post-hospital/post-operative follow-up | Home health nurse | blood pressure, pulse monitoring, auscultation | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Hays Medical Center | Hays | KS | Cox, 1997^ 4 ^, Lindberg, 1997^ 5 ^ | Chronic disease management, home health, nursing home care, physiological monitoring | Home health nurse | blood pressure, body temperature, visual monitoring of insulin injections, medication reminding, diet, hygiene, and mental health status | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines, coaxial/broadband cable
Internet Based Home Asthma Telemonitoring | New York | NY | Finkelstein,1998^ 6 ^,^ 7 ^ | Chronic disease management, physiological monitoring, specialist visits | Pulmonary care | spirometry tests | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Computer Based Automated Telephonic Home Monitoring System | West Lafayette | IN | Patel, 1992^ 8 ^ | chronic disease management, home health, post-hospital/post-operative follow-up | cardiology, home health nurse | body weight, body temperature, blood pressure | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Visiting Nurse Association of Los Angeles | Los Angeles | CA | Miller, 1995^ 9 ^ | home health, nursing home care, physiological monitoring | home health nurse, cardiology | body weight, body temperature, blood pressure, pulse, ECG
New England Medical Center | Boston | MA | Slipy, 1995^ 10 ^ | home health | home health nurse | unknown | 384 kbps | ISDN | terrestrial/phone lines
American Nursing Care Home Telemedicine | | | Crist, 1996, ^ 11 ^ | home health, nursing home care, physiological monitoring | home health nurse | body temperature, pulse-ox, blood pressure, ECG, auscultation, medication reminding,
Wellesley Central Hospital Hemodialysis Telemonitoring | Toronto | | Susman, 1997^ 10 ^ | chronic disease management, physiological monitoring, specialist consults or 2nd opinions | dialysis | dialysis data | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Kansas University Medical Center Home Health Pilot Project | Lenexa | KS | Allen, 1996^ 12 ^ | home health, nursing home care | home health nurse | blood pressure, blood glucose level, body temperature, visual monitoring of insulin injections, medication reminding | | | coaxial/broadband cable
Eisenhower Army Medical Center | | GA | Crawford, 1997^ 13 ^ | home health, nursing home care | home health nurse | vital signs
San Diego Veterans Affairs Medical Center | San Diego | CA | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring, ECG | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
San Francisco Veterans Affairs Medical Center | San Francisco | CA | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Washington, DC Veterans Affairs Medical Center | Washington | DC | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Omaha Veterans Affairs Medical Center | Omaha | NE | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Northport Veterans Affairs Medical Center | Northport | NY | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring, ECG | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Cleveland Veterans Affairs Medical Center | Cleveland | OH | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Altoona Veterans Affairs Medical Center | Altoona | PA | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Hot Springs Veterans Affairs Medical Center | Hot Springs | SD | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Central Texas Health Care System | Austin | TX | Rosenthal, 1997^ 1 ^ | chronic disease management, physiological monitoring, post-hospital/post-operative follow-up | cardiology | pacemaker monitoring | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines
Telelink and Mobilelink Transtelephonic ECG Systems | Ljublijana, Slovenia | | Ricci,1998^ 14 ^ | chronic disease management, diagnostic test interpretation, physiological monitoring, post-hospital/post-operative follow-up, specialist consults or 2nd opinions | cardiology | ECG | POTS (up to 54 kbps) | standard phone service (POTS) | terrestrial/phone lines

## References

1 Rosenthal BE. Telemedicine Sourcebook 1998: A resource guide for the practical application of telemedicine in the managed care marketplace. New York: Faulkner & Gray, Inc.; 1997.
2 Telemed Virtual Reality 1998 3(3).420454
3 Johnston B, Wheeler L, Deuser J Kaiser Permanente Medical Center's pilot Tele-Home Health Project Telemed Today 1997 5(4):16 7 10174243
4 Cox R, York ML Rural telemedicine - the electronic signal flows in both directions Best practices & benchmarking in healthcare: a practical journal for clinical & management applications 1997 2(1):28 32
5 Lindberg CC Implementation of in-home telemedicine in rural kansas: answering an elderly patient's needs J Am Med Inform Assoc 1997 4(1):14 7 61193 8988469
6 Finkelstein J, Hripcsak G, Cabrera MR. Patients' acceptance of Internet-based home asthma telemonitoring. Proceedings/AMIA Annual Symposium. 1998:336-40.
7 Finkelstein J, Hripcsak G, Cabrera M Telematic system for monitoring of asthma severity in patients' homes Medinfo 1998 9(Pt 1):272 6 10384460
8 Patel UH, Babbs CF A computer-based, automated, telephonic system to monitor patient progress in the home setting J Med Syst 1992 16(2-3):101 12 1402436
9 Miller PZ Home monitoring for congestive heart failure patients Caring 1995 14(8):53 4 10151219
10 Slipy SM Boston hospital using seven telemedicine systems within facility Health Manag Technol 1995 16(12):
11 Crist TM, Kaufman SB, Crampton KR Home telemedicine: a home health care agency strategy for maximizing resources Home Health Care Manag Pract 1996 8(4):1 9
12 Allen A, Roman L, Cox R, et al Home health visits using a cable television network: user satisfaction J Telemed Telecare 1996 2(Suppl 1):92 4 9375106
13 Crawford D. Georgia Medical Center delivers home health care. Telemed Virtual Reality. 1997;2(11).
14 Ricci MA, Knight SJ, Nutter B, et al Desktop telemedicine in vascular surgery: some preliminary findings Telemed J 1998 4(4):279 85 10220467