# Appendix E. Excluded Studies and the Reasons for Exclusion

Table E-1. Excluded from studies of evidence of diagnosis and management in store-and-forward telemedicine^a^

Source | Exclusion Reason
Ludwig, 1998^ 1 ^ | Teleradiology
DeCorato, 1995^ 2 ^ | Teleradiology
Franken, 1997^ 3 ^ | Teleradiology
Kagetsu, 1987^ 4 ^ | Teleradiology
Curtis, 1983^ 5 ^ | Teleradiology
Goldberg, 1993^ 6 ^ | Teleradiology
Roca, 1996^ 7 ^ | Telepathology
Olsson, 1995^ 8 ^ | Telepathology
Nordrum, 1995^ 9 ^ | Telepathology
Kuo, 1999^ 10 ^ | Telepathology
Raab, 1997^ 11 ^ | Telepathology
Adachi, 1996^ 12 ^ | Telepathology
Becker, 1993^ 13 ^ | Telepathology
Bilalovic, 1998^ 14 ^ | Telepathology
Della Mea, 1996^ 15 ^ | Telepathology
Della Mea, 1998^ 16 ^ | Telepathology
Galvez, 1998^ 17 ^ | Telepathology
Fujita, 1995^ 18 ^ | Telepathology
Weinstein, 1997^ 19 ^ | Telepathology
Weinberg, 1996^ 20 ^ | Telepathology
Jarris, 1994^ 21 ^ | Telepathology
Malone, 1997^ 22 ^ | Pediatric population
Patterson, 1998^ 23 ^ | Pediatric population
Nores, 1997^ 24 ^ | Pediatric population
Casey, 1998^ 25 ^ | Pediatric population
Finley, 1997^ 26 ^ | Pediatric population
Belmont, 1995^ 27 ^ | Pediatric population
Fyfe, 1998^ 28 ^ | Pediatric population
Fisk, 1996^ 29 ^ | Pediatric population
Wootton, 1997^ 30 ^ | Pediatric population
Reid, 1998^ 31 ^ | Insufficient report of methods
Harrison, 1998^ 32 ^ | Insufficient report of methods

a These studies were excluded following full text review of the article.

Table E-2. Excluded from studies of evidence of diagnosis and management in self-monitoring/testing telemedicine^a^

Source | Exclusion Reason
Antman, 1986^ 33 ^ | Not telemedicine by our definition

a These studies were excluded following full text review of the article.

Table E-3. Excluded from studies of evidence of diagnosis and management in clinician-interactive telemedicine^a^

Source | Exclusion Reason
Lee, 1999^ 34 ^ | Teleradiology
Yamamoto, 1996^ 35 ^ | Teleradiology
Loane, 1998^ 36 ^ | Preliminary report of 1-93
Conrath, 1977^ 37 ^ | Not our definition of telemedicine
Navein, 1997^ 38 ^ | Military population

a These studies were excluded following full text review of the article.

Table E-4. Excluded from studies of access^a^

Source | Exclusion Reason | Study Area
Finley, 1997^ 26 ^ | Pediatric sample | Store-and-forward
Fisk, 1996^ 29 ^ | Fetal telemedicine | Clinician-interactive physician services
Murdison, 1997^ 39 ^ | Pediatric sample | Clinician-interactive physician services
Rendina, 1998^ 40 ^ | Pediatric sample | Clinician-interactive physician services

a These studies were excluded following full text review of the article.

Appendix E-5. Excluded from studies of evidence of outcomes in self-monitoring testing telemedicine^a^

Source | Exclusion Reason
Marrero, 1995^ 41 ^ | Pediatric population
Di Biase, 1997^ 42 ^ | Obstetric population
Cartwright, 1992^ 43 ^ | Obstetric population
Alemi, 1996^ 44 ^ | Obstetric population
Brennan, 1998^ 45 ^ | No monitoring or testing
Brennan, 1999^ 46 ^ | No monitoring or testing
Coppola, 1993^ 47 ^ | No monitoring or testing
Albisser, 1996^ 48 ^ | Not telemedicine by our definition
Alemi, 1996^ 49 ^ | Not telemedicine by our definition
Sohn, 1997^ 50 ^ | Not telemedicine by our definition

a These studies were excluded following full text review of the article.

Appendix E-6. Excluded from studies of evidence of outcomes in clinician-interactive telemedicine^a^

Source | Exclusion Reason
Kofos, 1998^ 51 ^ | Pediatric population
Miyasaka, 1997^ 52 ^ | Pediatric population
Rendina, 1998^ 53 ^ | Pediatric population
Elford, 1999^ 54 ^ | Pediatric population

a These studies were excluded following full text review of the article.

Appendix E-7. Excluded from studies of satisfaction^a^

Source | Study technology | Description of satisfaction tool/method | Results | Comments
Alemi, 1996^ 49 ^ | CIT | 28 or 37 clients using Health Rap service completed satisfaction questionnaires | 53.6% found it extremely useful; 14.3% considerably 10.7% moderately useful; none slightly useful; 7% not useful | No information about the questionnaire appears; no breakdown of respondents and nonrespondents
Armstrong, 1997^ 55 ^ | CIT | General practitioners and consultants using teleradiology, videoconferencing, and telepresence in accident and emergency departments | GPs and consultants were satisfied with the information they received; both had confidence in the information; and both felt telemedicine improved patient care | No details of data analysis presented on satisfaction.
Blakeslee, 1998^ 56 ^ | CIT | All patients and family members of children (n is not specified) were asked to evaluate their satisfaction. | All participants indicated a positive experience and high acceptance. All consultants indicated satisfactory audio and visual communications | No indication of how provider satisfaction was obtained. No data to support findings.
Fisk,1996^ 29 ^ | CIT | 39 consultations in 29 women -a structured questionnaire was used to determine ...patient acceptability | Only one patient not referred responded that she would have preferred referral to teleconsultation. The service provided was acceptable to all users. | Unclear how many questionnaires were actually completed or how they were analyzed.
Johnson, 1998^ 57 ^ | CIT | Telesonographer rated quality of study and confidence in findings. Referring physician rated whether ultrasound was helpful. | Onsite radiologists were generally satisfied with quality of study and confident of sonographer's findings. Same was true of remote radiologists
Lambrecht, 1998^ 58 ^ | CIT | The level of satisfaction of orthopedic surgeons was measured after each consultation as being either unsatisfactory, satisfactory, or excellent. | All teleconsultations were ranked as satisfactory or excellent.
Lee, 1998^ 59 ^ | CIT | Emergency department referring physicians were asked to give satisfaction and comfort levels with teleradiology using a 7 point scale | Average 5.4 for satisfaction; 5.6 for comfort with teleradiology | Instrument used to gather data not reported in study, nor were specific findings.
Oakley, 1997^ 60 ^ | CIT | 98 of 104 patients completed satisfaction questionnaire | Most felt the project was adequately explained to them; that the technology was good; and that it decreased time and stress. | No information about the questionnaire appears; no breakdown of respondents and nonrespondents.
Oakley, 1998^ 61 ^ | CIT | Patients completed a questionnaire immediately after consultation. The dermatologist completed a "pro-forma" document. | Patients generally made favorable comments about teledermatology: saved time and money; reduced anxiety. Teledermatologists cited need for better equipment. | Some conflicting results noted.
Pacht, 1998^ 62 ^ | CIT | 40 consecutive outpatient referrals for pulmonology consultation | Patients satisfied with telemedicine. Patients somewhat more comfortable with traditional approach, but appreciated the convenience of teleconsult | 37 of 40 patients completed single survey after both teleconsult and traditional in-person consult. Minimal discussion of questionnaire design and analysis
Shanit, 1996^ 63 ^ | CIT | Telecardiology services for 93 GPs on 26 health centers to provide remote consultations. Included management of both acute and chronic problems | GPs rated the teleconsultation services high on efficiency, accessibility, response time, ECG analysis, cardiac consultation, and appropriate response to acute situation. They also identified multiple benefits to the technology. | Very rudimentary analysis of satisfaction questionnaires
Zhang, 1997^ 64 ^ | SM & T | Evaluation by 10 patients and 3 physicians answered an "evaluation interview" re: home ECG and BP telemonitoring system | Both groups very satisfied | Each group answered 5 yes/no questions re satisfied. Both groups had 100% response to "I am satisfied with the performance of the system."
Schulam, 1997^ 65 ^ | CIT | Central surgeons mentoring laparoscopic procedures for 7 patients at a remote site | The subjective impression of the central surgeons was that the system was adequate for telesurgical consultation. | Unknown how this impression was obtained. No information in paper about how satisfaction was assessed.
Harrison, 1998^ 32 ^ | CIT | 300 of 657 outpatient dermatology patients after attending both teledermatology evaluation and biopsies | 78% of patients answering questionnaire preferred teledermatology because it was more efficient. 85% were completely satisfied, and 96% would be happy to do it again. | Fewer than half the patients involved completed surveys after teledermatology consult; fewer that 1/4 completed surveys after operative treatment of skin lesions. No other information available re questionnaires or data re satisfaction.

a These studies were excluded following full text review of the article.

Table E-8. Excluded studies of cost^a^

Source | Study Area | Exclusion Reason
Brecht, 1996^ 66 ^ | Clinician-interactive | Prison study (vs. transport)
Rendina, 1997^ 67 ^ | Clinician-interactive | Pediatrics only
Rendina, 1998^ 53 ^ | Clinician-interactive | Pediatrics only
Finley, 1997^ 26 ^ | Store-and-forward | Pediatrics only
McCue, 1998 A&B^ 68 ^,^ 69 ^ | Clinician-interactive | Prison study (vs. transport)
Doty, 1996^ 70 ^ | Clinician-interactive | Prison study (vs. transport)
Zincone, 1997^ 71 ^ | Clinician-interactive | Prison study (vs. transport and escapes)
Crump, 1997^ 72 ^ | Clinician-interactive | Only cost to setup interactive video in academic department
Shultz, 1992 | Clinician-interactive | No primary economic data reported
Werner, 1998^ 73 ^ | Clinician-interactive | Feasibility study only, no actual TMED application
Shaw, 1995^ 74 ^ | Self-monitoring/testing | No actual cost data, only average reimbursement
Darkins, 1996^ 75 ^ | Clinician-interactive | No cost data, preliminary report only
Blakeslee, 1998^ 56 ^ | Clinician-interactive | Only application setup costs reported, no other costs
Patel, 1999 ^ 76 ^ | Clinician-interactive | Mariners at sea (not applicable to Medicare)
Brunicardi, 1998^ 77 ^ | Clinician-interactive | Prison study (vs. transport)
Taylor, 2000 ^ 78 ^ | Clinician-interactive | Expert opinion only for reduction in visits and time, no actual cost data
Reid, 1998^ 31 ^ | Store-and-forward | Radiology
Crowe, 1996^ 79 ^ | Store-and-forward | Radiology
Davis, 1997^ 80 ^ | Store-and-forward | Radiology

a These studies were excluded following full text review of the article.

## References

1 Ludwig K, Bick U, Oelerich M, et al Is image selection a useful strategy to decrease the transmission time in teleradiology? A study using 100 emergency cranial CTs Eur Radiol 1998 8(9):1719 21 9866793
2 DeCorato DR, Kagetsu NJ, Ablow RC Off-hours interpretation of radiologic images of patients admitted to the emergency department: efficacy of teleradiology Am J Roentgenol 1995 165(5):1293 6 7572522
3 Franken EA, Jr, Berbaum KS, Brandser EA, et al Pediatric radiology at a rural hospital: value of teleradiology and subspecialty consultation American Journal of Roentgenology 1997 168(5):1349 52 9129442
4 Kagetsu NJ, Zulauf DR, Ablow RC Clinical trial of digital teleradiology in the practice of emergency room radiology Radiol 1987 165(2):551 4
5 Curtis DJ, Gayler BW, Gitlin JN, et al Teleradiology: results of a field trial Radiol 1983 149(2):415 8
6 Goldberg MA, Rosenthal DI, Chew FS, et al New high-resolution teleradiology system: Prospective study of diagnostic accuracy in 685 transmitted clinical cases Radiol 1993 186(2):429 34
7 Roca OF, Pitti S, Cardama AD, et al Factors influencing distant tele-evaluation in cytology, pathology, conventional radiology and mammography Anal Cell Pathol 1996 10(1):13 23 8789266
8 Olsson S, Busch C A national telepathology trial in Sweden feasibility and assessment Arch Anat Cytol Pathol 1995 43(4):234 41 8526558
9 Nordrum I, Eide TJ Remote frozen section service in Norway Arch Anat Cytol Pathol 1995 43(4):253 6 8526562
10 Kuo RL, Aslan P, Dinlenc CZ, et al Secure transmission of urologic images and records over the Internet J Endourol 1999 13(3):141 6 10360490
11 Raab SS, Robinson RA, Snider TE, et al Telepathologic review: utility, diagnostic accuracy, and interobserver variability on a difficult case consultation service Mod Pathol 1997 10(6):630 5 9195582
12 Adachi H, Inoue J, Nozu T, et al Frozen-section services by telepathology: experience of 100 cases in the San-in District, Japan Pathol Int 1996 46(6):436 41 8869995
13 Becker RL, Jr., Specht CS, Jones R, et al Use of remote video microscopy (telepathology) as an adjunct to neurosurgical frozen section consultation Hum Pathol 1993 24(8):909 11 8375860
14 Bilalovic N, Paties C, Mason A Benefits of using telemedicine and first results in Bosnia and Herzegovina J Telemed Telecare 1998 4(Suppl 1):91 3 9640751
15 Della Mea V, Forti S, Puglisi F, et al Telepathology using Internet multimedia electronic mail: remote consultation on gastrointestinal pathology J Telemed Telecare 1996 2(1):28 34 9375039
16 Della Mea V, Beltrami CA Telepathology applications of the Internet multimedia electronic mail Med Inf 1998 23(3):237 44
17 Galvez J, Howell L, Costa MJ, et al Diagnostic concordance of telecytology and conventional cytology for evaluating breast aspirates Acta Cytol 1998 42(3):663 7 9622684
18 Fujita M, Suzuki Y, Takahashi M, et al The validity of intraoperative frozen section diagnosis based on video-microscopy (telepathology) Gen Diagn Pathol 1995 141(2):105 10 8548590
19 Weinstein MH, Epstein JI Telepathology diagnosis of prostrate needle biopsies Hum Pathol 1997 28(1):22 9 9013827
20 Weinberg DS, Allaert FA, Dusserre P, et al Telepathology diagnosis by means of digital still images: an international validation study Hum Pathol 1996 27(2):111 8 8617451
21 Jarris RF, Jr Satellite video system aids offshore treatment Health Manag Technol 1994 15(4):32 4 10132635
22 Malone FD, Nores JA, Athanassiou A, et al Validation of fetal telemedicine as a new obstetric imaging technique Am J Obstet Gynecol 1997 177(3):626 31 9322634
23 Patterson S, Botchway C Dental screenings using telehealth technology: a pilot study J Can Dent Assoc 1998 64(11):806 10 9879146
24 Nores J, Malone FD, Athanassiou A, et al Validation of first-trimester telemedicine as an obstetric imaging technology: a feasibility study Obstet Gynecol 1997 90(3):353 6 9277643
25 Casey F, Brown D, Corrigan N, et al Value of a low-cost telemedicine link in the remote echocardiographic diagnosis of congenital heart defects J Telemed Telecare 1998 4(Suppl 1):46 8 9640733
26 Finley JP, Sharratt GP, Nanton MA, et al Paediatric echocardiography by telemedicine-nine years' experience J Telemed Telecare 1997 3(4):200 4 9614734
27 Belmont JM, Mattioli LF, Goertz KK, et al Evaluation of remote stethoscopy for pediatric telecardiology Telemed J 1995 1(2):133 49 10165332
28 Fyfe DA, Emge F, Johnson G, et al Clinical validation of digital image compression levels for fetal echocardiograms for telemedicine Echocardiography 1998 15(4):363 8 11175049
29 Fisk NM, Sepulveda W, Drysdale K, et al Fetal telemedicine: six month pilot of real-time ultrasound and video consultation between the Isle of Wight and London Br J Obstet Gynaecol 1996 103(11):1092 5 8916994
30 Wootton R, Dornan J, Fisk NM, et al The effect of transmission bandwidth on diagnostic accuracy in remote fetal ultrasound scanning J Telemed Telecare 1997 3(4):209 14 9614736
31 Reid DS, Weaver LE, Sargeant JM, et al Telemedicine in Nova Scotia: report of a pilot study Telemed J 1998 4(3):249 58 9831749
32 Harrison PV, Kirby B, Dickinson Y, et al Teledermatology-high technology or not? J Telemed Telecare 1998 4(Suppl 1):31 2 9640726
33 Antman EM, Ludmer PL, McGowan N, et al Transtelephonic electrocardiographic transmission for management of cardiac arrhythmias Am J Cardiol 1986 58(10):1021 4 3776841
34 Lee BR, Allaf M, Moore R, et al Clinical decision making using teleradiology in urology Am J Roentgenol 1999 172(1):19 22 9888731
35 Yamamoto LG, Ash KM, Boychuk RB, et al Personal computer teleradiology interhospital image transmission of neonatal radiographs to facilitate tertiary neonatology telephone consultation and patient transfer J Perinatol 1996 16(4):292 8 8866301
36 Loane MA, Gore HE, Bloomer SE, et al Preliminary results from the Northern Ireland arms of the UK Multicentre Teledermatology Trial: is clinical management by realtime teledermatology possible? J Telemed Telecare 1998 4(Suppl 1):3 5 9640716
37 Conrath DW, Dunn EV, Bloor WG, et al A clinical evaluation of four alternative telemedicine systems Behav Sci 1977 22(1):12 21 405004
38 Navein J, Hagmann J, Ellis J Telemedicine in support of peacekeeping operations overseas: an audit Telemed J 1997 3(3):207 14 10174345
39 Murdison KA Telemedicine: a useful tool for the pediatric cardiologist Telemed J 1997 3(2):179 84 10168283
40 Rendina MC. The effect of telemedicine on neonatal intensive care unit length of stay in very low birthweight infants. Proceedings/AMIA Annual Symposium. 1998:111-5.
41 Marrero DG, Vandagrief JL, Kronz K, et al Using telecommunication technology to manage children with diabetes: The computer-linked outpatient clinic (CLOC) study The Diabetes Educator 1995 21(4):313 19 7621734
42 di Biase N, Napoli A, Sabbatini A, et al Telemedicine in the treatment of diabetic pregnancy Ann Ist Super Sanita 1997 33(3):347 51 9542261
43 Cartwright W Objective measurement of anxiety in hypertensive pregnant women managed in hospital and in the community British Journal of Obstetrics and Gynaecology 1992 99(March):182 5 1606113
44 Alemi F, Stephens RC, Javalghi RG, et al A randomized trial of a telecommunications network for pregnant women who use cocaine Med Care 1996 34(10 Suppl):OS10 20 8843933
45 Brennan JA, Kealy JA, Gerardi LH, et al A randomized controlled trial of telemedicine in an emergency department J Telemed Telecare 1998 4(Suppl 1):18 20 9640721
46 Brennan JA, Kealy JA, Gerardi LH, et al Telemedicine in the emergency department: A randomized controlled trial J Telemed Telecare 1999 5(1):18 22 10505365
47 Coppola MP, Lawee M Management of obstructive sleep apnea syndrome in the home. The role of portable sleep apnea recording Chest 1993 104(1):19 25 8325068
48 Albisser AM, Harris RI, Sakkal S, et al Diabetes intervention in the information age Med Inf 1996 21(4):297 316
49 Alemi F, Stephens RC, Muise K, et al Educating patients at home. Community Health Rap Med Care 1996 34(10 Suppl):OS21 31 8843934
50 Sohn C, Beldermann F, Wallwiener D, et al Telecommunication - a possibility to improve prenatal and gynecological ultrasound diagnosis - preliminary results Zentralbl Gynakol 1997 119(4):177 80 9206924
51 Kofos D, Pitetti R, Orr R, et al Telemedicine in pediatric transport: a feasibility study Pediatrics 1998 102(5):
52 Miyasaka K, Suzuki Y, Sakai H, et al Interactive communication in high-technology home care: videophones for pediatric ventilatory care Pediatrics 1997 99(1):
53 Rendina MC, Downs SM, Carasco N, et al Effect of telemedicine on health outcomes in 87 infants requiring neonatal intensive care Telemed J 1998 4(4):345 51 10220475
54 Elford R. The child telepsychiatry project. In: 4th International Conference on the Medical Aspects of Telemedicine; 1999 June 6-10; Jerusalem, Israel: Tokyo: International Society for Telemedicine; 1999. p. 11.
55 Armstrong IJ, Haston WS Medical decision support for remote general practitioners using telemedicine J Telemed Telecare 1997 3(1):27 34 9139758
56 Blakeslee DB, Grist WJ, Stachura ME, et al Practice of otolaryngology via telemedicine Laryngoscope 1998 108(1 I):1 7 9432058
57 Johnson MA, Davis P, McEwan AJ, et al Preliminary findings from a teleultrasound study in Alberta Telemed J 1998 4(3):267 76 9831751
58 Lambrecht CJ, Canham WD, Gattey PH, et al Telemedicine and orthopaedic care. A review of 2 years of experience Clin Orthop 1998(348):228 32
59 Lee JK, Renner JB, Saunders BF, et al Effect of real-time teleradiology on the practice of the emergency department physician in a rural setting: initial experience Acad Radiol 1998 5(8):533 8 9702263
60 Oakley AM, Astwood DR, Loane M, et al Diagnostic accuracy of teledermatology: results of a preliminary study in New Zealand N Z Med J 1997 110(1038):51 3 9076285
61 Oakley AM, Duffill MB, Reeve P Practising dermatology via telemedicine N Z Med J 1998 111(1071):296 9 9760955
62 Pacht ER, Turner JW, Gailiun M, et al Effectiveness of telemedicine in the outpatient pulmonary clinic Telemed J 1998 4(4):287 92 10220468
63 Shanit D, Cheng A, Greenbaum RA Telecardiology: supporting the decision-making process in general practice J Telemed Telecare 1996 2(1):7 13 9375036
64 Zhang Y, Bai J, Zhou X, et al First trial of home ECG and blood pressure telemonitoring system in Macau Telemed J 1997 3(1):67 72 10166447
65 Schulam PG, Docimo SG, Saleh W, et al Telesurgical mentoring. Initial clinical experience Surg Endosc 1997 11(10):1001 5 9381336
66 Brecht RM, Gray CL, Peterson C, et al The University of Texas Medical Branch-Texas Department of Criminal Justice Telemedicine Project: findings from the first year of operation Telemed J 1996 2(1):25 35 10165347
67 Rendina MC, Long WA, deBliek R Effect size and experimental power analysis in a paediatric cardiology telemedicine system J Telemed Telecare 1997 3(Suppl 1):56 7 9218385
68 Hampton CL, Mazmanian PE, McCue MJ, et al Telemedicine in use. The Medical College of Virginia, The Powhatan Correctional Center and the Blackstone Family Practice Center Va Med Q 1996 123(3):167 70 8752956
69 McCue MJ, Mazmanian PE, Hampton C, et al The case of Powhatan Correctional Center/Virginia Department of Corrections and Virginia Commonwealth University/Medical College of Virginia Telemed J 1997 3(1):11 7 10166440
70 Doty E, Zincone LH, Jr., Balch DC. Telemedicine in the North Carolina prison system. A cost-benefits analysis. Stud Health Technol Inf. 1996;29:239-41.
71 Zincone LH, Jr., Doty E, Balch DC Financial analysis of telemedicine in a prison system Telemed J 1997 3(4):247 55 10176005
72 Crump WJ, Tessen RJ Communication in integrated practice networks: using interactive video technology to build the medical office without walls Tex Med 1997 93(3):70 5 9062464
73 Werner A, Anderson LE Rural telepsychiatry is economically unsupportable: the Concorde crashes in a cornfield Psychiatr Serv 1998 49(10):1287 90 9779895
74 Shaw DK, Sparks KE, Jennings HS, 3rd, et al Cardiac rehabilitation using simultaneous voice and electrocardiographic transtelephonic monitoring Am J Cardiol 1995 76(14):1069 71 7484865
75 Darkins A, Dearden CH, Rocke LG, et al An evaluation of telemedical support for a minor treatment centre J Telemed Telecare 1996 2(2):93 9 9375069
76 Patel T. A cost-benefit analysis of the effect of shipboard telemedicine in a selected oceanic region. Telemed J. 1999.
77 Brunicardi BO Financial analysis of savings from telemedicine in Ohio's prison system Telemed J 1998 4(1):49 54 9599074
78 Taylor P An assessment of potential effect of a teledermatology system J Telemed Telecare 2000 6(Supplement 1):74 6
79 Crowe BL, Hailey DM, de Silva M Teleradiology at a children's hospital: a pilot study J Telemed Telecare 1996 2(4):210 6 9375061
80 Davis MC Teleradiology in rural imaging centres J Telemed Telecare 1997 3(3):146 53 9489109