# Appendix D. Characteristics of Well-Designed Studies for Each Component of the Analytic Framework

This appendix describes critical characteristics of well-designed studies for links in the analytic framework. It concentrates on criteria intended to reduce the potential for biases.

## General Design Considerations

### 1) Subjects

Subjects (both physicians and patients) in pilot studies of telemedicine applications may not be representative of patients who would be candidates for the application in everyday care. Bias can occur when studies recruit patients who are willing to participate but might not need the service.

### 2) Comparison Groups

One important consideration across all links in the analytic framework is, What is the appropriate comparison group? A natural comparison group for a population having the option of a telemedicine application is a group without the application that is similar across time and distance.

When other comparison groups are used, the potential for selection bias may be high -- for example, when a comparison is made between the same patients before and after a telemedicine encounter. In this case, the provider determines when the patient is ready to have an encounter. If the provider delays the telemedicine encounter until the patient is well along in the healing process, the patient may be expected to have a more successful encounter than if the patient had been scheduled from the first day of the provider interaction.

Selection bias is also very likely in studies that use historical, or concurrent but non-randomized, controls. Not all patients who have a particular disease or condition are equally good candidates for an intervention. Many telemedicine interactions are used to decide whether or not to transport a patient from a remote hospital to a more centralized higher-order medical center. A patient with a very severe disease or condition is more likely to be transported without waiting for the telemedicine consultation. In this situation, comparison of patients who had a teleconsult with those transported immediately would be biased. If the death rate is higher in those transported immediately, this may well reflect the severity of the disease or condition instead of the telemedicine service.

### 3) Allocation of sample units to comparison groups

While random allocation of sample units to comparison groups is arguably the ideal allocation schema, in some circumstances non-random allocation may also be used effectively in studies of telemedicine applications. Comparison of two states at two time points is an example of a non-random allocation. Provided the geographic regions are generally comparable with respect to factors such as age distribution, socio-economic status, race, and so on, random selection of states, smaller geographic units, or even patients, is not necessary for a well-designed study.

## Technical Feasibility and Diagnostic Accuracy

Technical feasibility refers to comparison of images or other telemedicine assessments to similar assessments performed in a more traditional manner. Diagnostic accuracy takes technical feasibility one step further and evaluates decisions that clinicians arrive at using telemedicine assessments rather than traditional assessments. For this discussion, diagnostic accuracy may also include treatment plans made using information from assessments and, ultimately, patient outcomes (such as hospital length of stay or adverse experiences). Because study design approaches are similar for these two links in the analytic framework except for potential comparisons of patient outcomes following diagnoses, we begin by discussing both of these areas and then discuss patient outcomes related to diagnostic accuracy.

Two criteria are important for a well-designed study of technical feasibility.^ 5 ^ The first is whether or not the range of study patients covers the range of patients for whom the telemedicine application is intended. If this criterion is not met, there is a potential for selection bias. For example, a teleradiology application may be used to assist in making a decision whether or not to transport a patient from a regional hospital to a tertiary medical center. If there are patients whose condition is sufficiently severe that they would be transported without the teleradiology, then the application has not demonstrated technical feasibility in these more severe patients. Similarly, if this application is used to make preliminary diagnoses, then its use provides no evidence of diagnostic efficacy in more severe patients.

The second criterion is whether or not there is an independent, blinded comparison with a reference standard. The reference standard for a telemedicine application is the traditional application for which the telemedicine application is intended to substitute. Thus, a well-designed study should ensure that there is an independent and, if possible, blinded comparison of the two assessments. For example, having the same radiologist review the teletransmitted image and the original image does not constitute independent assessment and should be avoided. For technical feasibility, both independence and blinding are preferable.

Two other criteria are also useful for a well-designed study of technical feasibility or diagnostic accuracy. First, the results of the test being performed should not influence the decision to use the reference standard. In most telemedicine applications, this is unlikely to occur, since a telemedicine image will usually be compared to an already existing image. Secondly, the details of the test should allow another researcher to replicate the results. Thus, if there are criteria used to make specific diagnoses, these criteria should be listed completely to allow others to replicate the research.

## Clinical Outcomes

The usual process of evaluation begins with a demonstration of efficacy. That is, in a carefully controlled situation, can a telemedicine application improve health, access, satisfaction, or so forth? Alternatively, if the telemedicine application is designed to be equivalent to conventional care, this equivalence should be demonstrated. A study designed to show equivalence requires adequate statistical power to demonstrate with a sufficient degree of assurance that the difference between two alternatives is less than a pre-specified target. Studies that have inadequate power (i.e., in which the sample size is too small) cannot be used to provide evidence of the equivalence of two alternative applications. An underpowered study provides little more evidence than does an assumption of equivalence.

Once the efficacy of a telemedicine application has been demonstrated, the next step is to demonstrate the effectiveness of the application. That is, once the application has been shown to work under carefully selected and controlled conditions, will the application work "in the real world" in a broad range of patients under a broad range of conditions? Suppose, for example, that the primary care providers in a phase III randomized efficacy trial of a tele-endoscopy consult are carefully selected based on prior training and interest in endoscopy. While this selected group may provide evidence that a tele-endoscopy consult can work, unselected primary care providers may lack the interest and training to perform as well. In this case, the tele-endoscopy consult may not be effective in the broader group of primary care providers.

To evaluate outcomes, all patients in an effectiveness trial should be accounted for. If some subjects in an assessment failed to complete a survey evaluation, are lost to followup, or are otherwise unaccounted for, the conclusions of the trial could change, since these subjects may have responded differently than those who did respond or stayed in the study. If subjects are randomized within a trial, then intent-to-treat analyses should be performed. That is, the primary analysis should be based on the group to which the subject was randomly assigned. If 20% of subjects assigned to use a telemedicine application chose instead to travel for more traditional care, these subjects (and their associated costs) should be attributed to the telemedicine application. Lack of compliance may be a feature of the telemedicine application in regular usage and thus should be included. An analysis that classifies subjects who are treated may also be performed, but as a secondary analysis. If there is a difference between the two analyses, further research may be needed to reduce the non-compliance and improve the outcomes of the telemedicine application. Similarity of the comparison groups at the start of the study should be assessed and, where differences occur, adjustment should be made in the analyses to account for such differences. Also, the treatment received by each subject (other than the telemedicine or traditional application) should be as similar as possible. For example, if the subject receiving a teleconsult is given an opportunity for an additional face-to-face meeting with a specialist, then a subject using the traditional approach should have the same option. Finally, while it may not be possible to blind a subject to the type of application (telemedicine or traditional), the person performing an assessment on such a subject should be blinded as to the subject's group assignment.

## Patient Satisfaction

Many principles that apply to health-related quality of life^ 4 ^ are also applicable to patient satisfaction. The first principle in considering a satisfaction study is whether or not the investigators measure aspects of satisfaction that are important to the patient. For example, communication may be very important to the patient having a teleconsult, while physician expertise may be of less importance. If the satisfaction assessment focuses on physician expertise but does not address communication, then it misses an important component. A second consideration is whether or not the satisfaction instrument has been validated. If the instrument does not measure satisfaction as intended, the result will not be useful. To the extent that there are existing validated instruments that evaluate patient satisfaction, telemedicine evaluations should employ such instruments. Evaluating patient satisfaction with a telemedicine application should focus on satisfaction, not merely on the technology. Thus, a satisfaction tool already in use in a traditional application should be applied to the telemedicine application. It may be appropriate to add additional questions to explore specific aspects of the telemedicine application, but it is also important to assess satisfaction compared to a traditional application that is not based on the technology. This is analogous to including both generic and disease-specific quality-of-life tools in a quality-of-life evaluation.

## Economic Evaluation

The literature contains several good reviews of economic evaluations.^1-3,6^ For example, the text by Gold et al.^ 1 ^ is a comprehensive review of economic evaluations, and Drummond et al^ 2 ^ have recently updated another good overview. The paper by Udvarhelyi^ 3 ^ is a shorter primer of economic evaluations and was used to assess the quality of the economic evaluations reviewed in this report. For this appendix, the 10-item checklist by Drummond et al. (Box 3.1) is used as a guideline to planning economic evaluations. The principles of Gold et al. and Udvarhelyi are all similar.

### 1) Well-defined question in answerable form

In most cases, both the costs and the consequences of a telemedicine application are of interest. For setting up a feasibility study, costs alone may be adequate, but to demonstrate the cost-effectiveness of an intervention, both costs and consequences should be considered. The viewpoint or perspective of the evaluation should also be considered -- that is, whose costs and whose consequences are to be evaluated? Gold et al.^ 1 ^ recommend that the societal perspective be included in all economic evaluations. Other perspectives may be those of a provider (or health care system), the patient, or a payor (such as the Health Care Financing Administration for Medicare). Finally, does the study involve comparisons to alternative options?

### 2) Comprehensive description of comparative alternatives

If the study involves comparison of alternative options (e.g., a telemedicine encounter compared to a traveling physician), are all aspects of each option considered? If there are aspects that are constant across all options, these can be omitted from the evaluation. In general, an evaluation should fully address who did what to whom, where, how often, and to what effect. To the extent that any of these pieces cannot be assessed in an economic evaluation, the specification of the alternatives may be incomplete. For example, a common approach taken in the economic evaluation of teleconsults in radiology and other areas related to emergency medicine is to consider a teleconsult made prior to a decision to transport a patient from a "remote" hospital (remote from the consultant) to a higher-order centralized medical center (where the consultant is on staff) and compare it to transporting all emergency cases. No paper reviewed the subsequent consequences of transport versus treatment at a remote site. Because there are various potential adverse experiences from both the decision to transport and the decision to treat locally, the realization of these potential adverse experiences needs to be evaluated.

### 3) Prior demonstration of effectiveness

A cost-effectiveness study is usually not the ideal study in which to evaluate the effectiveness of an intervention. If an economic evaluation assumes (implicitly or explicitly) that the effectiveness of each alternative is known, some justification for the effectiveness should be provided. Because the effectiveness of an intervention has already been described under step 3 of the analytic framework, prior proof of effectiveness will be assumed for economic evaluations.

It is possible to evaluate both effectiveness and cost-effectiveness in a single study. For example, in a randomized control trial of a therapy, investigators may also collect economic data to assess its cost-effectiveness. However, an evaluation that attempts to demonstrate both effectiveness and cost-effectiveness must be carefully designed in order to ensure that, in attempting to perform two tasks, the study does neither task well. If there is no prior proof of the effectiveness of a telemedicine application, however, then the lower costs of the telemedicine application do not demonstrate that the application is cost-effective, since the effectiveness remains unanswered. This is very common in the telemedicine literature review, especially in studies in which reduced numbers of emergency transports is used to illustrate the cost advantages of a telemedicine application.

### 4) Identification of all important and relevant costs for each alternative

For telemedicine applications, several types of costs need to be evaluated. Costs of implementation and maintenance of the application are one set of important costs. These costs are typically cited in the current literature either as actual costs demonstrated over time or assumed on the basis of a particular proposal and set of assumptions. Other associated costs should also be included. The costs of adverse experiences are an important class of costs that is usually not considered in the current telemedicine literature. If costs associated with transport versus local treatment are included in an economic evaluation, then the adverse experiences of these two options should also be included, since these experiences may not be equal among those who receive a teleconsult and are transported after evaluation and those who are transported without teleconsult. For example, the teleconsult group may have a delay in transport or may have an incomplete or unsuccessful teleconsult. This can lead to an incorrect decision, or the group treated locally may not receive the same quality of care as a patient transported to a higher-order medical center. Also, some of those transported without teleconsult may have adverse experiences related to the transport or to other aspects of care. In other telemedicine encounters, inaccurate diagnoses or inappropriate treatment plans resulting from telemedicine may lead to adverse events that may be avoided by a direct consult. Given that adverse events may influence economic evaluations in various ways, it seems imperative to include adverse experiences in economic evaluations of telemedicine. Another potential difference between patients transported and patients treated locally is the cost of care. Per-day hospital costs and length of stay may differ between a remote hospital and a large centralized medical center. To the extent that these differ, these values need to be included in economic evaluations.

Other costs associated with telemedicine evaluations also need to be included. The time horizon for an economic evaluation is important. Equipment may become obsolete in a few years, since technology changes tend to be very rapid in telemedicine. Thus, time horizons for telemedicine applications may be relatively short (perhaps 5 years or less). For longer time horizons, both replacement of equipment and retraining of staff are likely to be important costs in an evaluation.

### 5) Accurate measurement of costs and consequences

Once all relevant cost items and consequences have been identified, each individual component should be measured. If a particular component is omitted from a measurement, is that component thereby excluded from the model? If so, the particular measurement may need revision, or an alternative method of assessment may be required. For example, if a particular prescription medication is an integral part of a telemedicine application but Medicare has yet to start a prescription benefit for elderly beneficiaries, the Medical Statistical System (MSS) would be unable to track utilization of the prescription. Thus, the MSS would not provide an appropriate measure for this medication.

Special circumstances may make a measurement difficult. In such a circumstance, consideration should be given to what approach was used and whether the approach adequately addresses the difficulties. For example, a researcher may mail a survey to beneficiaries to assess whether or not the prescription was obtained. If the response rate is low (because of the delay from the telemedicine interaction to the incorporation of the data into the MSS and subsequent mailing of the survey to the beneficiary), this may be a poor way to assess the cost impact of the prescription from the patient or societal perspective.

### 6) Credible values for costs and consequences

All sources of values should be clearly identified with respect to course and to time (e.g., year). Referenced data sources are of higher quality than other potential sources (e.g., personal communication). Where possible, market value costs (how much is expended) are preferable to charges (how much is billed), although the effort to obtain the former may be prohibitive in some cases. Valuations of health preferences or utilities are often incorporated into economic evaluations. Again, the effort to obtain these may be prohibitive. If utilities are included in the evaluation, then whose utilities they are and how they were assessed should be carefully considered and reported.

### 7) Adjusted costs and consequences for differential timing

If the costs or consequences of a telemedicine intervention accrue over a period of more than one year, the costs and consequences should be discounted. The cost of setting up a telemedicine application is often amortized over 2 or more years. Annual costs of operation and maintenance are also usually included in an evaluation. These costs should be discounted to reflect the decrease in future value of money. If there are other components of an application that have duration in excess of one year, these should also be discounted. For example, a self-monitoring/testing telediabetes application will likely treat patients for several years. Consequences such as improved compliance and subsequent lower Hemoglobin A1C levels should also be discounted in each year following the initial year of the evaluation. Typical discount rates in the literature are 3%^ 1 ^ and 5%.^ 2 ^

### 8) Incremental analyses of alternatives of interest

Comparisons of one option to another should be performed in an incremental fashion. That is, one should compare the additional benefits and consequences of an application relative to another with the additional costs associated with the application. In other words, a telemedicine application should be compared to a standard-of-care model and not to no therapy at all (unless no therapy is the current standard of care).

### 9) Allowance for uncertainty of estimates used to evaluate

Many variables used to perform economic evaluations have a degree of uncertainty associated with them. The uncertainty may be due to random chance (as when a parameter is estimated from a sample with an associated confidence interval) or to a potential range of values when no other information is available. Sensitivity analyses should be used to evaluate the impact of uncertainty on the resulting conclusions. Sensitivity analyses allow one to assess whether or not the lack of certainty of a particular value will drastically change the conclusions of the evaluation.

### 10) Addressing all concerns of users

When reporting results of the evaluation, researchers should report sufficient information so that those reviewing the evaluation can understand all assumptions that were made and the sources of all data. Attention to such detail will allow reviewers of the evaluation (including policymakers) to compare the evaluation to other work and to arrive at the most meaningful conclusions.

## References

1 Gold M, Siegel J, Russell L, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
2 Drummond M, O'Brien B, Stoddart G, et al. Methods for the Economic Evaluation of Health Care Programmes. Second Edition ed. Oxford: Oxford University Press; 1997.
3 Udvarhelyi IS, Colditz GA, Rai A, et al Cost-effectiveness and cost-benefit analyses in the medical literature. Are the methods being used correctly? Ann Intern Med 1992 116(3):238 44 1530808
4 Drummond MF, Richardson WS, O'Brien BJ, Levine M, Heyland D, for the Evidence-Based Medicine Working Group. User's guide to the medical literature. XIII. How to use an article on economic analysis of clinical practice. A. Are the results of the study valid?. JAMA. 1997A;277:1552-7. [pmid: 9153371].
5 Guyatt GH, Naylor CD, Juniper E, Heyland DK, Jaeschke R, Cook DJ, for the Evidence-Based Medicine Working Group. User's guide to the medical literature. XII. How to use articles about health-related quality of life. JAMA. 1997;277:1232-7. [pmid: 9103349].
6 Jaeschke R, Guyatt G, Sackett DL for the Evidence-Based Medicine Working Group. User's guide to the medical literature. III. How to use an article about a diagnostic test. Are the results of the study valid?. JAMA. 1994;271:389-91. [pmid: 8283589].