# Appendix C. Database Variables

Main entry table

Field Name | Data Type | Description
ID | AutoNumber | ID Number that Uniquely Identifies each program
TMPROG | Text | Program Name
ORGAFFIL | Number | Auto lookup looks at Affiliations table
ORGNAME | Text | Organization Name
NETWRK#2 | Text | Networked to an other program
ADDRESS | Text | Address
CITY | Text | City
ST | Text | State
ZIPCODE | Text | ZIP Code or Postal Code
COUNTRY | Text | Country
CONTACT | Text | Contact Person
PHONE | Text | Phone Number
FAX | Text | Fax
EMAIL | Text | Email Address
WWW | Text | URL (Web Address) for Program
YEARST | Text | Year Started
XSTATE1 | Number | State in which the program is doing patient/provider telemedicine consults (Autolookup field that searches the states of America table)
XSTATE2 | Text | State in which the program is doing patient/provider telemedicine consults (Autolookup field that searches the states of America table)
XSTATE3 | Text | State in which the program is doing patient/provider telemedicine consults (Autolookup field that searches the states of America table)
XSTATE4 | Text | State in which the program is doing patient/provider telemedicine consults (Autolookup field that searches the states of America table)
XSTATE5 | Text | State in which the program is doing patient/provider telemedicine consults (Autolookup field that searches the states of America table)
FOREIGN | Text | Name of the foreign country where program operates
FOREIGN1 | Number | Geographic Area in which the program is doing patient/provider telemedicine consults (Autolook up field that searches the Foreign Countries) (Combo Box)
FOREIGN2 | Number | Geographic Area in which the program is doing patient/provider telemedicine consults (Autolook up field that searches the Foreign Countries) (Combo Box)
FOREIGN3 | Number | Geographic Area in which the program is doing patient/provider telemedicine consults (Autolook up field that searches the Foreign Countries) (Combo Box)
FOREIGN4 | Number | Geographic Area in which the program is doing patient/provider telemedicine consults (Autolook up field that searches the Foreign Countries) (Combo Box)
FOREIGN5 | Number | Geographic Area in which the program is doing patient/provider telemedicine consults (Autolook up field that searches the Foreign Countries) (Combo Box)
CLINACT1 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
CLINACT2 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
CLINACT3 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
CLINACT4 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
CLINACT5 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
CLINACT6 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
CLINACT7 | Number | Clinical Activity in which the program is involved (Autolookup field from Clinical Activity Table) (Combo Box)
SITETOTL | Number | Total number of active sites
SITEREQ | Number | Active sites that request Telemedicine consults
SITEPROV | Number | Active sites that provide telemedicine consultation
SITEOWN | Number | Number of sites affiliated with the program through ownership
SITEMGMT | Number | Number of sites affiliated to program through Management :
SITEINV | Number | Number of sites that have financed their own participation in the program :
SYSUSECL | Number | Clinical Use
SYSUSEAD | Number | Administrative Use
SYSUSADM | text | Administrative Details
SYSUSAD1 | Number | Auto lookup field looks up table "System used for Administration" (Combo Box)
SYSUSEED | Number | Educational Use
SYSUSEDU | text | Educational details
SYSUSED1 | Number | Auto lookup field looks up table "System used for Education" (Combo Box)
SYSUSED2 | Number | Auto lookup field looks up table "System used for Education" (Combo Box)
SYSUSERE | Number | Research Use
SYSUSRES | text | Research Details
SYSUSRE1 | Number | Auto lookup field looks up table "System used for Research" (Combo Box)
SYSREVCL | Text | Revenue from Clinical Use
SYSRVCL1 | Number | Auto lookup field looks up table "Revenue from Clinics" (Combo Box)
SYSREVAD | Text | Revenue from Administrative Use
SYSRVAD1 | Number | Auto lookup field looks up table "Revenue from Administration" (Combo Box)
SYSREVED | Text | Revenue from Educational Use
SYSRVED1 | Number | Auto lookup field looks up table "Revenue from Education" (Combo Box)
SYSREVRE | Text | Revenue from Research Use
SYSREVRE1 | Number | Auto lookup field looks up table "Revenue from Research" (Combo Box)
FUNDING | Text
TCOMSERV | Number | Telecom Service type (Auto Lookup field that looks up the names of the Services) (Combo Box)
TCOMSERV2 | Number | Telecom Service type (Auto Lookup field that looks up the names of the Services) (Combo Box)
TCOMSERV3 | Number | Telecom Service type (Auto Lookup field that looks up the names of the Services) (Combo Box)
TCBDWDTH | Number | Most Common Bandwidth. Auto Lookup field that looks up the BandWidths (Combo Box)
TCMEDIUM | Number | Telecomm Medium. Auto Lookup field that looks up the Medium (Combo Box)
TCOMCOST | Currency | Monthly recurring cost
TCOSTPAY | Number | Who Pays the cost
StartupCost | Currency | Start-up Cost
OngoingCost | Currency | Ongoing Cost
EQUPTYP1 | Number | Communications Equipment used by Program (Auto look up in Equipment type table) (Combo Box)
EQUPTYP2 | Number | Communications Equipment used by Program (Auto look up in Equipment type table) (Combo Box)
EQUPTYP3 | Number | Communications Equipment used by Program (Auto look up in Equipment type table) (Combo Box)
EQPRIPH1 | Number | Peripheral Devices used by Program (Auto look up in Peripheral Devices table) (Combo Box)
EQPRIPH2 | Number | Peripheral Devices used by Program (Auto look up in Peripheral Devices table) (Combo Box)
EQPRIPH3 | Number | Peripheral Devices used by Program (Auto look up in Peripheral Devices table) (Combo Box)
EQPOTHER | Text | Other Equipment if any
Ref1 | Text | Reference numbers of the articles
Ref2 | Text | Reference numbers of the articles
Ref3 | Text | Reference numbers of the articles
Ref4 | Text | Reference numbers of the articles
Ref5 | Text | Reference numbers of the articles
Ref6 | Text | Reference numbers of the articles
Ref7 | Text | Reference numbers of the articles
Ref8 | Text | Reference numbers of the articles
Ref9 | Text | Reference numbers of the articles
DataSys | Memo | Data Systems to Track Utilization:
QualStd | Memo | Quality Standards
LegalCons | Memo | Legal Considerations
PtpopServ | Memo | Patient population Served
Comments | Memo | Comments

Facility table

Field Name | Data Type | Description
ID | Number | Unique identifier for the programs
Type of Facility | Text | List the type of facility (Combo Box) Here you can select from the list of available options.
NoofSites | Number | Number of Sites
State/Country | Text | State where the facility operates
Year | Text | Year
Noof Patients | Number | No. of patients seen for the above year
Noof Consults | Number | No. of Consults for the above year
NoofProv | Number | No. of providers providing the above mentioned facility

Telemonitoring table

Field Name | Data Type | Description
ID | Number | Unique Identifiers for the program
TypeofActivity | Number | Type of Activity (Combo Box) Here you can select from the list of available options.
SM&T | Text | Yes or No for Self Monitoring and Testing
AssocClinAct | Number | Associated Clinical Activity (Combo Box) Here you can select from the list of available options.
AssocClinSpec | Number | Associated Clinical Specialty (Combo Box) Here you can select from the list of available options.
ProgramLocation | Text | Location of the functioning of the activity
StRegionServed | Text | Regions served by the activity
NoofBaseStations | Number | Number of base stations
Year | Text | Year
Noofptserved | Number | Number of patients served in the above year
NoofNursePtInteractions | Number | Number of Nurse/patient interactions for the above year

Clinical Specialty table

Field Name | Data Type | Description
ID | Number | Unique Identifier for the Programs. It is a foreign key from the table Catalog
ClinicalSpecialty | Text | Clinical Specialty (Combo Box) Here you can select from the list of available options.
NoofProv | Number | Number of providers who do consults in this specialty
Year | Text | Year
NoofPt | Number | Number of patients seen for the above year
NoofConsults | Number | No. of consults for the above Year
TechnologyUsed | Number | Technology Used (Combo Box) Here you can select from the list of available options.
AssocClinAct1 | Number | 1st Associated Clinical Activity (Combo Box) Here you can select from the list of available options.
AssocClinAct2 | Number | 2nd Associated Clinical Activity (Combo Box) Here you can select from the list of available options.
AssocClinAct3 | Number | 3rd Associated Clinical Activity (Combo Box) Here you can select from the list of available options.