# Appendix B. Literature Search Strategies

## Broad search strategy

1. exp telemedicine/
2. telemedicine.mp.
3. telehealth.tw.
4. remote consultation$.mp.
5. 1 or 2 or 3 or 4
6. limit 5 to english language
7. 5 not 6
8. limit 7 to abstracts
9. 6 or 8

## Supplemental search strategy

1. exp telemedicine/
2. telemedicine.mp.
3. telehealth.tw.
4. remote consultation$.mp.
5. 1 or 2 or 3 or 4
6. exp home care services/
7. home nursing/
8. 6 or 7
9. exp therapy, computer-assisted/
10. exp computers/
11. exp computer communication networks/
12. exp medical informatics/
13. exp telecommunications/
14. exp monitoring, physiologic/
15. monitor$.tw.
16. blood glucose self-monitoring/
17. self-examination/
18. self exam$.tw.
19. self monitor$.tw.
20. self test$.tw.
21. 14 or 15 or 16 or 17 or 18 or 19 or 20
22. tele$.tw.
23. (remote or offsite or distance).tw. tw=abstract, title
24. rural population/
25. rural health services/
26. hospitals, rural/
27. rural.tw.
28. 22 or 23 or 24 or 25 or 26 or 27
29. 21 and 28
30. 9 or 10 or 11 or 12 or 13 or 29
31. 8 and 30
32. 31 not 5
33. limit 32 to english language
34. 32 not 33
35. limit 34 to abstracts
36. 33 or 35