# Appendix A. Procedure Code Review

As telemedicine services improve and demonstrate efficacy, they are likely to be reimbursed by Medicare and private insurers. There also needs to be, as stated in the main report, additional research in telemedicine's effectiveness. Both of these require a means for tracking telemedicine services utilization in patient care setting. A historic way to measure utilization is to track procedure codes used in claims for reimbursement by health care providers and organizations (e.g., hospitals, clinics, home health agencies).

An additional analysis of this study was to review selected procedure codes for their applicability to telemedicine services in the two of the three study areas: self-monitoring/testing and clinician-interactive services. We specifically identified which codes could be applied to these services and whether any services were currently being provided that could not be represented by the current codes.

Our analysis covered codes from Current Procedural Terminology (CPT -- a trademark of the American Medical Association, AMA) 1999^ (2) ^ and the Health Care Financing Administration (HCFA) Common Procedure Coding System (HCPCS).^ (1) ^ The HCPCS consists of codes for services covered by Medicare but not defined in the CPT system. Level I of HCPCS is the CPT system. Level II of HCPCS consists of over 2,400 additional codes added by HCFA for Medicare reimbursement, and has been in use since 1983. Level III of HCPCS consists of additional codes added by individual Medicare carriers.

The codes reviewed included those from the pathology, medicine, and evaluation and management chapters of CPT, along with selected HCPCS codes. (The CPT and HCPCS codes for inclusion were specified in our contract with the Agency for Healthcare Research and Quality.) The excluded codes were either for services inappropriate for telemedicine (e.g., surgery) or those already covered by Medicare (e.g., telemedicine specialty consultations in primary care Health Professional Shortage Areas which are currently reimbursed). The included HCPCS codes represented radiologic or other procedures whose applicability fell under teletesting. Examples of this included G0030-G0047 (variants of cardiac PET imaging) and G104-G107 (variants of colon cancer screening).

Two individuals, a physician with expertise in internal medicine and medical informatics (WRH) and a nurse with expertise in emergency nursing and emergency department management (SES), reviewed all specified CPT and HCPCS codes for their suitability to self-monitoring/testing and clinician-interactive services. The reviewers examined the codes separately and then reconciled their differences. They required that the potential telemedicine application could involve a healthcare professional and utilize electronic data rather than audio telephone data exchange and/or an automated advice system. These individuals, involved in all facets of the evidence report described in the main body of the report, also sought to identify services provided that could not be adequately described by existing codes.

The first step in this analysis was to create broad categories of CPT codes (but less than a full chapter) to be able to characterize groups of services. Table 1 lists these categories of CPT code groups. Each line contains a range of codes for the clinical activity group. The final column denotes whether some or all of the codes were excluded from our analysis because services within them are already covered by Medicare as described above.

There were 171 CPT or HCPCS codes that could be applicable to self-monitoring/testing in the home or other remote sites (Table 2). Several CPT pathology codes were appropriate because there are portable units on the market that can perform various blood tests. These devices can measure chemistries, arterial blood gases, electrolytes, and other hematological parameters, and the number of physiological indicators that can be measured in the home is constantly increasing. Many of these measurements can be taken in a telecare program with the patient, a caregiver, or a health assistant collecting the data and transmitting it for analysis, and such procedures would be applicable for reimbursement. For our analysis, the list of codes was limited to those that represent what is currently being done in self-monitoring/testing practice. We did not identify any self-monitoring/testing services currently being provided that could not be represented by these codes.

There were 120 CPT codes that could be applicable to clinician-interactive services (Table 3). No HCPCS codes were applicable. Most of the CPT codes were Medicine and Evaluation & Management codes, representing a variety of services in which telemedicine could substitute for a face-to-face medical encounter. As with self-monitoring/testing telemedicine, we did not identify any clinician-interactive services currently being provided that could not be represented by these codes.

We conclude that current CPT and HCPCS codes are adequate for describing the types of telemedicine services covered by the study areas of this report. Modifiers will be needed to all separation of telemedicine and non-telemedicine services when utilization is being measured from claims databases.

Table A-1. Categories of CPT codes and their exclusion from the analysis

Range | Category | Section of CPT code definition | Codes excluded from review by contract
00100-01999 | Anesthesia | Anesthesia | All
10000-69990 | Surgical or invasive diagnostic or therapeutic procedure | Surgery | All
70000-79999 | Radiologic or other imaging procedure | Radiology | Some
80049-87999 | Blood or urine fluid assessment | Pathology
88000-88099 | Autopsy | Pathology
88104-88199 | Cytopathology | Pathology
88230-88241 | Tissue culture | Pathology
88245-88299 | Cytogenetics | Pathology
88300-88399 | Surgical pathology | Pathology
89050-89359 | Assessment of other body fluids | Pathology
90281-90799 | Diagnostic or therapeutic injection | Medicine | All
90801-90911 | Psychotherapy | Medicine | Some
90918-90999 | ESRD services | Medicine
91000-91299 | Gastroenterology procedures | Medicine
92002-92499 | Opthalmologic procedures | Medicine | Some
92502-92599 | Otolaryngolic procedures | Medicine | Some
92950-93990 | Cardiovascular procedures | Medicine
94010-94799 | Pulmonary procedures | Medicine
95004-95199 | Allergy and immunologic procedures | Medicine
95805-95830 | Sleep studies | Medicine
95831-95999 | Electrophysiology | Medicine
96100-96117 | Psychological testing | Medicine
96400-96549 | Chemotherapy | Medicine
96900-96999 | Phototherapy | Medicine
97000-97799 | Physical therapy | Medicine
98925-98943 | Manipulative therapy | Medicine
99000-99082 | Special services | Medicine
99090-99090 | Analysis of information stored in computers | Medicine
99100-99199 | Anesthesia or sedation | Medicine | Some
99201-99215 | Outpatient visit | E&M
99217-99239 | Inpatient visit | E&M
99241-99245 | Office consultation | E&M | All
99251-99263 | Inpatient consultation | E&M | All
99271-99275 | Confirmatory consultation | E&M | All
99281-99288 | Emergency department visit | E&M | All
99291-99298 | Critical care visit | E&M
99301-99333 | Nursing or domiciliary facility visit | E&M
99341-99350 | Home visit | E&M
99354-99359 | Prolonged physician evaluation | E&M | All
99360-99373 | Management coordination | E&M | All
99374-99380 | Physician supervision of patient at home, hospice, or nursing facility | E&M | All
99381-99429 | Preventive medicine services | E&M | All
99431-99440 | Newborn services | E&M | All
99450-99499 | Disability evaluation | E&M | All

Note: The CPT and HCPCS codes for inclusion were specified in our contract with the Agency for Healthcare Research and Quality.

Table A-2. Self-monitoring/testing HCPCS and CPT codes

Range | Category | Section
HCPCS
G0004 | ECG transm phys review & int
G0005 | ECG 24 hour recording
G0006 | ECG transmission & analysis
G0007 | ECG phy review & interpret
G0015 | Post symptom ECG tracing
G0016 | Post symptom ECG md review
G0108 | Diab manage trn per indiv
G0109 | Diab manage trn ind/group
CPT
80049-87999 | Blood or urine fluid assessment | Pathology
81000 | URINALYSIS, NONAUTO, W/SCOPE
81001 | URINALYSIS, AUTO, W/SCOPE
81002 | URINALYSIS, NONAUTO W/O SCOPE
81003 | URINALYSIS, AUTO, W/O SCOPE
81005 | URINALYSIS
81007 | URINE SCREEN FOR BACTERIA
81050 | URINALYSIS, VOLUME MEASURE
82270 | TEST FECES BLOOD
82273 | TEST BLOOD, OTHER SOURCE
82705 | FATS/LIPIDS, FECES QUALITATI
82947 | ASSAY QUANTITATIVE, GLUCOSE
82948 | REAGENT STRIP/BLOOD GLUCOSE
82962 | GLUCOSE BLOOD TEST
85013 | HEMATOCRIT
85610 | PROTHROMBIN TIME
90801-90911 | Psychotherapy | Medicine
90801 | PSYCH INTERVIEW, DIAGNOSTIC
90802 | PSYCH INTERVIEW, INTERACTIVE
90804 | PSYCH TX, OFFICE, 20-30 MIN
90805 | PSYCH TX, OFFICE, 20-30 MIN
90806 | PSYCH TX, OFFICE, 45-50 MIN
90807 | PSYCH TX, OFFICE, 45-50 MIN
90808 | PSYCH TX, OFFICE, 75-80 MIN
90809 | PSYCH TX, OFFICE, 75-80 MIN
90810 | PSYCH TX, OFFICE, 20-30 MIN
90811 | PSYCH TX, OFFICE, 20-30 MIN
90812 | PSYCH TX, OFFICE, 45-50 MIN
90813 | PSYCH TX, OFFICE, 45-50 MIN
90814 | PSYCH TX, OFFICE, 75-80 MIN
90815 | PSYCH TX, OFFICE, 75-80 MIN
90816 | PSYCH TX, HOSP, 20-30 MIN
90817 | PSYCH TX, HOSP, 20-30 MIN
90818 | PSYCH TX, HOSP, 45-50 MIN
90819 | PSYCH TX, HOSP, 45-50 MIN
90821 | PSYCH TX, HOSP, 75-80 MIN
90822 | PSYCH TX, HOSP, 75-80 MIN
90823 | PSYCH TX, HOSP, 20-30 MIN
90824 | PSYCH TX, HOSP, 20-30 MIN
90826 | PSYCH TX, HOSP, 45-50 MIN
90827 | PSYCH TX, HOSP, 45-50 MIN
90828 | PSYCH TX, HOSP, 75-80 MIN
90829 | PSYCH TX, HOSP, 75-80 MIN
90845 | PSYCHOANALYSIS
90846 | FAMILY THERAPY W/O PATIENT
90847 | FAMILY THERAPY W/PATIENT
90849 | MULT FAMILY GROUP THERAPY
90853 | GROUP PSYCHOTHERAPY
90857 | GROUP PSYCHOTHERAPY
90862 | MEDICATION MANAGEMENT
90901 | BIOFEEDBACK TRAIN, ANY METHD
90911 | BIOFEEDBACK PERI/URO/RECTAL
90918-90999 | ESRD services | Medicine
90918 | ESRD RELATED SERVICES, MONTH
90919 | ESRD RELATED SERVICES, MONTH
90920 | ESRD RELATED SERVICES, MONTH
90921 | ESRD RELATED SERVICES, MONTH
90922 | ESRD RELATED SERVICES, DAY
90923 | ESRD RELATED SERVICES, DAY
90924 | ESRD RELATED SERVICES, DAY
90925 | ESRD RELATED SERVICES, DAY
90989 | DIALYSIS TRAINING/COMPLETE
90993 | DIALYSIS TRAINING/INCOMPLETE
92502-92599 | Otolaryngolic procedures | Medicine
92506 | SPEECH/HEARING EVALUATION
92507 | SPEECH/HEARING THERAPY
92508 | SPEECH/HEARING THERAPY
92510 | REHAB FOR EAR IMPLANT
92950-93990 | Cardiovascular procedures | Medicine
93012 | TRANSMIT ECG
93014 | REPORT ON TRANSMITTED ECG
93224 | ECG MONITOR/REPORT, 24 HRS
93225 | ECG MONITOR/RECORD, 24 HRS
93226 | ECG MONITOR/REPORT, 24 HRS
93227 | ECG MONITOR/REVIEW, 24 HRS
93230 | ECG MONITOR/REPORT, 24 HRS
93231 | EXG MONITOR/RECORD, 24 HRS
93232 | ECG MONITOR/REPORT, 24 HRS
93233 | ECG MONITOR/REVIEW, 24 HRS
93235 | ECG MONITOR/REPORT, 24 HRS
93236 | ECG MONITOR/REPORT, 24 HRS
93237 | ECG MONITOR/REVIEW, 24 HRS
93268 | ECG RECORD/REVIEW
93270 | ECG RECORDING
93271 | ECG/MONITORING AND ANALYSIS
93272 | ECG/REVIEW, INTERPRET ONLY
93278 | ECG/SIGNAL-AVERAGED
93724 | ANALYZE PACEMAKER SYSTEM
93731 | ANALYZE PACEMAKER SYSTEM
93732 | ANALYZE PACEMAKER SYSTEM
93733 | TELEPHONE ANALYSIS PACEMAKER
93734 | ANALYZE PACEMAKER SYSTEM
93735 | ANALYZE PACEMAKER SYSTEM
93736 | TELEPHONE ANALYSIS PACEMAKER
93737 | ANALYZE CARDIO/DEFIBRILLATOR
93738 | ANALYZE CARDIO/DEFIBRILLATOR
93797 | CARDIAC REHAB
93798 | CARDIAC REHAB/MONITOR
94010-94799 | Pulmonary procedures | Medicine
94010 | BREATHING CAPACITY TEST
94014 | PATIENT RECORDED SPIROMETRY
94015 | PATIENT RECORDED SPIROMETRY
94016 | REVIEW PATIENT SPIROMETRY
94060 | EVALUATE WHEEZING
94070 | EVALUATE WHEEZING
94150 | VITAL CAPACITY TEST
94200 | LUNG FUNCTION TEST (MBC/MVV)
94240 | RESIDUAL LUNG CAPACITY
94660 | POS AIRWAY PRESSURE, CPAP
94662 | NEG PRESSURE VENTILATION, CN
94664 | AEROSOL/VAPOR INHALATIONS
94665 | AEROSOL/VAPOR INHALATIONS
94667 | CHEST WALL MANIPULATION
94668 | CHEST WALL MANIPULATION
94760 | MEASURE BLOOD OXYGEN LEVEL
94761 | MEASURE BLOOD OXYGEN LEVEL
94762 | MEASURE BLOOD OXYGEN LEVEL
94770 | EXHALED CARBON DIOXIDE TEST
94772 | BREATH RECORDING INFANT
95805-95830 | Sleep studies | Medicine
95806 | SLEEP STUDY, UNATTENDED
96100-96117 | Psychological testing | Medicine
96100 | PSYCHOLOGICAL TESTING
96105 | ASSESS APHASIA
96110 | DEVELOPMENT TEST, LIMITED
96111 | DEVELOPMENT TEST, EXTENDED
96115 | NEUROBEHAVIOR STATUS EXAM
96117 | NEUROPYSCH TEST BATTERY
96900-96999 | Phototherapy | Medicine
96902 | TRICHOGRAM
97000-97799 | Physical therapy | Medicine
97001 | PT EVALUATION
97002 | PT RE-EVALUATION
97003 | OT EVALUATION
97004 | OT RE-EVALUATION
97010 | HOT/COLD PACKS THERAPY
97012 | MECHANICAL TRACTION THERAPY
97110 | THERAPEUTIC EXERCISES
97112 | NEUROMUSCULAR REEDUCATION
97113 | AQUATIC THERAPY/EXERCISES
97116 | GAIT TRAINING THERAPY
97124 | MASSAGE THERAPY
97139 | PHYSICAL MEDICINE PROCEDURE
97504 | ORTHOTIC TRAINING
97520 | PROSTHETIC TRAINING
97530 | THERAPEUTIC ACTIVITIES
97535 | SELF CARE MANAGMENT TRAINING
97537 | COMMUNITY/WORK REINTEGRATION
97542 | WHEELCHAIR MANAGMNT TRAINING
97545 | WORK HARDENING
97546 | WORK HARDENING ADD-ON
97703 | PROSTHETIC CHECKOUT
97750 | PHYSICAL PERFORMANCE TEST
97770 | COGNITIVE SKILLS DEVELOPMENT
97799 | PHYSICAL MEDICINE PROCEDURE
99301-99333 | Nursing or domiciliary facility visit | E&M
99321 | REST HOME VISIT NEW PATIENT
99322 | REST HOME VISIT NEW PATIENT
99323 | REST HOME VISIT NEW PATIENT
99331 | REST HOME VISIT EST PATIENT
99332 | REST HOME VISIT EST PATIENT
99333 | REST HOME VISIT EST PATIENT
99341-99350 | Home visit | E&M
99341 | HOME VISIT NEW PATIENT
99342 | HOME VISIT NEW PATIENT
99343 | HOME VISIT NEW PATIENT
99344 | HOME VISIT NEW PATIENT
99345 | HOME VISIT NEW PATIENT
99347 | HOME VISIT EST PATIENT
99348 | HOME VISIT EST PATIENT
99349 | HOME VISIT EST PATIENT
99350 | HOME VISIT EST PATIENT

Note: The CPT and HCPCS codes for inclusion were specified in our contract with the Agency for Healthcare Research and Quality.

Table A-3. Clinician-interactive services CPT codes

Range | Category | Section
80049-87999 | Blood or urine fluid assessment | Pathology
80500 | LAB PATHOLOGY CONSULTATION
80502 | LAB PATHOLOGY CONSULTATION
88300-88399 | Surgical pathology | Pathology
88321 | MICROSLIDE CONSULTATION
88323 | MICROSLIDE CONSULTATION
88325 | COMPREHENSIVE REVIEW DATA
88329 | PATHOLOGY CONSULT IN SURGERY
88331 | PATHOLOGY CONSULT IN SURGERY
88332 | PATHOLOGY CONSULT IN SURGERY
90801-90911 | Psychotherapy | Medicine
90801 | PSYCH INTERVIEW, DIAGNOSTIC
90802 | PSYCH INTERVIEW, INTERACTIVE
90804 | PSYCH TX, OFFICE, 20-30 MIN
90805 | PSYCH TX, OFFICE, 20-30 MIN
90806 | PSYCH TX, OFFICE, 45-50 MIN
90807 | PSYCH TX, OFFICE, 45-50 MIN
90808 | PSYCH TX, OFFICE, 75-80 MIN
90809 | PSYCH TX, OFFICE, 75-80 MIN
90810 | PSYCH TX, OFFICE, 20-30 MIN
90811 | PSYCH TX, OFFICE, 20-30 MIN
90812 | PSYCH TX, OFFICE, 45-50 MIN
90813 | PSYCH TX, OFFICE, 45-50 MIN
90814 | PSYCH TX, OFFICE, 75-80 MIN
90815 | PSYCH TX, OFFICE, 75-80 MIN
90816 | PSYCH TX, HOSP, 20-30 MIN
90817 | PSYCH TX, HOSP, 20-30 MIN
90818 | PSYCH TX, HOSP, 45-50 MIN
90819 | PSYCH TX, HOSP, 45-50 MIN
90821 | PSYCH TX, HOSP, 75-80 MIN
90822 | PSYCH TX, HOSP, 75-80 MIN
90823 | PSYCH TX, HOSP, 20-30 MIN
90824 | PSYCH TX, HOSP, 20-30 MIN
90826 | PSYCH TX, HOSP, 45-50 MIN
90827 | PSYCH TX, HOSP, 45-50 MIN
90828 | PSYCH TX, HOSP, 75-80 MIN
90829 | PSYCH TX, HOSP, 75-80 MIN
90845 | PSYCHOANALYSIS
90846 | FAMILY THERAPY W/O PATIENT
90847 | FAMILY THERAPY W/PATIENT
90849 | MULT FAMILY GROUP THERAPY
90853 | GROUP PSYCHOTHERAPY
90857 | GROUP PSYCHOTHERAPY
90862 | MEDICATION MANAGEMENT
90901 | BIOFEEDBACK TRAIN, ANY METHD
90911 | BIOFEEDBACK PERI/URO/RECTAL
90918-90999 | ESRD services | Medicine
90918 | ESRD RELATED SERVICES, MONTH
90919 | ESRD RELATED SERVICES, MONTH
90920 | ESRD RELATED SERVICES, MONTH
90921 | ESRD RELATED SERVICES, MONTH
90922 | ESRD RELATED SERVICES, DAY
90923 | ESRD RELATED SERVICES, DAY
90924 | ESRD RELATED SERVICES, DAY
90925 | ESRD RELATED SERVICES, DAY
90989 | DIALYSIS TRAINING/COMPLETE
90993 | DIALYSIS TRAINING/INCOMPLETE
92002-92499 | Opthalmologic procedures | Medicine
92002 | EYE EXAM NEW PATIENT
92004 | EYE EXAM NEW PATIENT
92012 | EYE EXAM EST PATIENT
92014 | EYE EXAM W/TREATMENT
92502-92599 | Otolaryngolic procedures | Medicine
92506 | SPEECH/HEARING EVALUATION
92507 | SPEECH/HEARING THERAPY
92508 | SPEECH/HEARING THERAPY
92510 | REHAB FOR EAR IMPLANT
96100-96117 | Psychological testing | Medicine
96100 | PSYCHOLOGICAL TESTING
96105 | ASSESS APHASIA
96110 | DEVELOPMENT TEST, LIMITED
96111 | DEVELOPMENT TEST, EXTENDED
96115 | NEUROBEHAVIOR STATUS EXAM
96117 | NEUROPYSCH TEST BATTERY
96900-96999 | Phototherapy | Medicine
96902 | TRICHOGRAM
97000-97799 | Physical therapy | Medicine
97001 | PT EVALUATION
97002 | PT RE-EVALUATION
97003 | OT EVALUATION
97004 | OT RE-EVALUATION
97010 | HOT/COLD PACKS THERAPY
97012 | MECHANICAL TRACTION THERAPY
97110 | THERAPEUTIC EXERCISES
97112 | NEUROMUSCULAR REEDUCATION
97113 | AQUATIC THERAPY/EXERCISES
97116 | GAIT TRAINING THERAPY
97124 | MASSAGE THERAPY
97139 | PHYSICAL MEDICINE PROCEDURE
97504 | ORTHOTIC TRAINING
97520 | PROSTHETIC TRAINING
97530 | THERAPEUTIC ACTIVITIES
97535 | SELF CARE MANAGMENT TRAINING
97537 | COMMUNITY/WORK REINTEGRATION
97542 | WHEELCHAIR MANAGMNT TRAINING
97545 | WORK HARDENING
97546 | WORK HARDENING ADD-ON
97703 | PROSTHETIC CHECKOUT
97750 | PHYSICAL PERFORMANCE TEST
97770 | COGNITIVE SKILLS DEVELOPMENT
97799 | PHYSICAL MEDICINE PROCEDURE
99201-99215 | Outpatient visit | E&M
99201 | OFFICE VISIT NEW PATIENT
99202 | OFFICE VISIT NEW PATIENT
99203 | OFFICE VISIT NEW PATIENT
99204 | OFFICE VISIT NEW PATIENT
99205 | OFFICE VISIT NEW PATIENT
99211 | OFFICE VISIT EST PATIENT
99212 | OFFICE VISIT EST PATIENT
99213 | OFFICE VISIT EST PATIENT
99214 | OFFICE VISIT EST PATIENT
99215 | OFFICE VISIT EST PATIENT
99301-99333 | Nursing or domiciliary facility visit | E&M
99321 | REST HOME VISIT NEW PATIENT
99322 | REST HOME VISIT NEW PATIENT
99323 | REST HOME VISIT NEW PATIENT
99331 | REST HOME VISIT EST PATIENT
99332 | REST HOME VISIT EST PATIENT
99333 | REST HOME VISIT EST PATIENT
99341-99350 | Home visit | E&M
99341 | HOME VISIT NEW PATIENT
99342 | HOME VISIT NEW PATIENT
99343 | HOME VISIT NEW PATIENT
99344 | HOME VISIT NEW PATIENT
99345 | HOME VISIT NEW PATIENT
99347 | HOME VISIT EST PATIENT
99348 | HOME VISIT EST PATIENT
99349 | HOME VISIT EST PATIENT
99350 | HOME VISIT EST PATIENT

Note: The CPT and HCPCS codes for inclusion were specified in our contract with the Agency for Healthcare Research and Quality.

## References

Health Care Financing Administration (HCFA). Common Procedure Coding System (HCPCS). [pmcid: 92788].
American Medical Association. Common Procedural Terminology (CPT) 1999 Edition. [pmcid: 166167].