# Appendixes

Appendix A. Procedure Code Review

Appendix B. Literature Search Strategies

Appendix C. Database Variables

Appendix D. Characteristics of Well-Designed Studies for Each Component of the Analytic Framework

Appendix E. Excluded Studies and the Reasons for Exclusion

Appendix F. Self-Monitoring/Testing Programs

Appendix G. Task Order Personnel