# Evidence Tables

Evidence Table 1. General characteristics of all studies

Characteristics | Number of Studies
Number of studies first identified from each source
Medline | 119
CINAHL | 13
EMBASE | 10
Citation Lists | 6
HealthSTAR | 1
Author contact | 1
Cochrane RCT Registry | 0
Year of publication
1971-75 | 2
1976-80 | 7
1981-85 | 4
1986-90 | 16
1991-95 | 47
1996-99 | 74
Other | 0
Language of publication
English | 143
Non-English | 7
Source of funding ^1^
Professional Organization | 20
Government Agency | 17
Other | 9
Industry | 4
Charity | 2
Consumer Organization | 0
Unclear | 6
Not reported | 99
Number of studies investigating each AHRQ research question ^2^
When should weaning be initiated? | 31
What criteria should be used to initiate the weaning process? | 34
What are the most effective methods of weaning from mechanical ventilation? | 120
What is the value of clinical practice algorithms and computers in expeditious weaning? | 16
What are the optimal roles of nonphysician health care professionals in facilitating safe and expeditious weaning? | 18

1 More than one source of funding may apply to each study

2 Individual studies may address one or more of the AHRQ research questions

Evidence Table 2. Population characteristics for all studies

Characteristics | Number of Studies
Health care setting
Tertiary care hospital (university/teaching hospital ) | 131
Community hospital | 8
Long term ventilatory care facility | 1
Other | 10
Type of intensive care unit(s) ^1^
Medical | 51
Surgical | 40
Cardiovascular | 24
Trauma | 6
Coronary care | 3
Other | 61
Country in which study was centered
USA | 79
Canada | 15
France | 12
Spain | 9
Great Britain | 6
Japan | 4
Australia | 3
Germany | 3
Italy | 3
Taiwan | 3
South Africa | 2
Switzerland | 2
Argentina | 1
Belgium | 1
Chile | 1
Finland | 1
Greece | 1
Hong Kong | 1
India | 1
Netherlands | 1
Russia | 1
Singapore | 1
Sweden | 1
Turkey | 1
Number of participating hospitals
1 | 125
2 | 7
3 | 4
8 | 1
14 | 1
30 | 1
Unclear | 6
Not reported | 5
Number of participating intensive care units
1 | 108
2 | 10
3 | 3
>4 | 6
Unclear | 14
Not reported | 9
Population age group ^2^
Adult | 134
Paediatric | 13
Elderly only | 4
Neonatal mixed with pediatric | 0
Diagnostic categories of patients ^3^
COPD | 63
Asthma | 19
Pneumonia | 51
CHF | 41
Acute lung injury | 22
Hemodynamic instability | 19
Post-operative | 57
Neuromuscular | 16
Neurological | 43
Airway protection | 10
Coronary artery bypass surgery | 53
Cardiac valvular surger | 31
Congenital heart disease | 7
Infant respiratory distress syndrome | 3
Trauma | 33
Other | 79
Unclear | 2
Not reported | 7

1 More than one ICU type may apply per study.

2 More than one population age may apply per study.

3 More than one diagnostic category may apply per study.

Evidence Table 3. Design characteristics for all studies

Characteristics | No. of Studies
Study design
RCT, parallel | 45
RCT, crossover | 1
Non-RCT, contemporaneous controls | 5
Non-RCT, historical controls | 18
Case series | 74
Review Article | 0
Unclear | 0
Other | 7
Direction of investigation
Prospective | 129
Retrospective | 20
Unclear | 1
Not reported | 0

Evidence Table 4. Interventions characteristics for all studies

Characteristics | Number of Studies
Point of initiation of intervention ^1^
Time of intubation | 18
Specified duration of mechanical ventilation | 15
"Ready to wean" by time criteria | 4
"Ready to wean" by vital signs criteria | 30
"Ready to wean" by lung mechanics criteria | 36
"Ready to wean" by gas exchange criteria | 37
"Ready to wean" by scores/composite measures criteria | 1
"Ready to wean" clinical impression | 48
Failed wean | 13
"Possibly ready to extubate" by time criteria | 0
"Possibly ready to extubate" by vital signs criteria | 9
"Possibly ready to extubate" by lung mechanics criteria | 8
"Possibly ready to extubate" by gas exchange criteria | 17
"Possibly ready to extubate" by scores/composite measures criteria | 1
"Possibly ready to extubate" clinical impression | 22
Failed extubation | 11
Successful extubation | 9
Unclear | 7
Not reported | 2
Type of intervention
Weaning criteria | 40
Weaning protocol - general | 19
Weaning protocol - computerized | 3
Weaning mode of ventilation | 17
Weaning technology | 3
Noninvasive ventilation for weaning purposes | 4
Tracheostomy - present or absent | 0
Tracheostomy - variable timing | 0
Extubation criteria | 20
Extubation - variable timing | 11
Drug intervention | 21
Other | 12

1 More than one point of initiation of intervention may apply per study

Evidence Table 5. Characteristics of included randomized clinical trials

Characteristics | Number of Studies
Method of randomization
Randomization table (+/-computer generated) | 17
Coin flip | 1
Alternating treatment allocation | 0
Not clearly reported | 19
Not reported at all | 7
Concealment of allocation
Not concealed | 0
Concealed by independent randomization center | 0
Concealed by sealed opaque envelopes | 6
Sealed unspecified envelopes | 5
Unclear | 1
Not reported | 32
Blinding
RT blinded | 1
RT not blinded | 6
RT blinding unclear | 2
RT blinding not reported | 35
Nurses blinded | 2
Nurses not blinded | 6
Nursing blinding unclear | 2
Nursing blinding not reported | 34
Physicians blinded | 6
Physicians not blinded | 7
Physician blinding unclear | 1
Physician blinding not report | 30
Reasons for study withdrawals reported for each arm
Yes | 17
No | 1
Unclear | 1
Probably no withdrawals | 25
Interventions | No. of Studies
Studies Comparing Alternative Discontinuation Assessment Strategies
1. T-piece | 6
2. T-piece trial 30 minutes | 1
3. T-piece trial 120 minutes | 1
4. CPAP 5 (or 4) | 5
5. CPAP 10 | 1
6. PS 7 | 1
7. IMV 4 and CPAP 5 | 2
Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support
8. PS (to maintain minute volume) | 2
9. IMV (to maintain minute volume) | 1
10. Carbon dioxide mandatory ventilation | 1
11. Noninvasive ventilation | 2
12. Controlled ventilation | 1
Studies Comparing Alternative Ventilation Modes for Weans Lasting Less than 48 Hours
13. Extubation + NPPV | 0
14. PS | 6
15. SIMV | 4
16. Multiple daily T-piece trials | 2
17. Once daily T-piece trial | 1
18. SIMV + PS | 1
19. IMV | 2
20. MMV | 1
Studies Comparing Weaning Protocols with Physician Directed Weaning
21. Protocol by nurse and RT | 1
22. Physician directed weaning | 3
23. Daily screening +/-T-piece trial | 1
24. Computer-directed weaning | 1
Studies Comparing Early vs Late Extubation Following Cardiac Surgery
25. Early | 11
26. Late | 11
Studies Evaluating Steroids to Prevent Postextubation Airway Complications
27. Steroids | 7
28. No steroids | 7
Studies of Enteral Nutrition
29. High fat-low carbohydrate feeds | 2
30. Isocaloric feeds | 2
Miscellaneous Interventions
31. Nasal BiPAP | 2
32. CPAP | 1
33. Routine chest physiotherapy | 2
34. Recombinant growth hormone | 1
35. No recombinant growth hormone | 1
36. Pulse oximetry and capnography | 1
37. Periodic ABG | 1
38. Relaxation biofeedback | 1
39. No relaxation biofeedback | 1
40. Tactile/verbal stimulation from nurse | 1
41. No tactile/verbal stimulation from nurse | 1
42. BiPAP/APRV wean | 1
43. Acupuncture | 1
44. PSV wean | 1
Outcome Measurements | No. of Studies
Major Outcomes
1. ICU mortality | 6
2. Hospital mortality | 8
3. 30-day mortality | 2
4. 60-day mortality | 1
5. 90-day mortality | 1
6. Reintubation rate | 27
7. Extubation rate | 15
8. Nonextubation rate at various times | 2
9. Self-extubation | 1
10. Successful T-piece trial | 1
11. ICU length of stay | 14
12. ICU discharge at 24 or 48 h | 1
13. Hospital length of stay | 11
14. Duration of mechanical ventilation | 18
15. Duration of mechanical ventilation per day | 1
16. Duration of weaning | 8
17. Duration of weaning per day | 1
18. Duration of successful wean | 1
19. No. of patients requiring mechanical ventilation >7 days | 1
20. Mechanical ventilation for >21 days | 2
21. Successful weaning at day 12 | 1
22. Composite outcome: failed weaning = death or reintubation | 1
23. Duration of intubation | 3
Minor Outcomes
24. Tidal volume | 1
25. Change in tidal volume | 1
26. Respiratory rate | 2
27. Change in respiratory rate | 2
28. Vital capacity | 1
29. Maximal inspiratory pressure at weaning termination | 1
30. Arterial partial pressure of carbon dioxide (PaCO_2_) | 1
31. Change in PaCO_2_ | 1
32. Stridor score | 1
33. Postextubation stridor | 2
34. Postextubation stridor at 10 min | 1
35. Postextubation stridor at 6 h | 1
36. Postextubation at 12 h | 1
37. Postextubation stridor 24 h | 1
38. Laryngospasm | 1
39. Croup score at 10 min following extubation | 1
40. Croup score at 6 hours following extubation | 1
41. Croup score at 12 hours following extubation | 1
Outcome Measurements | No. of Studies
Minor Outcomes
42. Croup score at 24 hours following extubation | 1
43. Postextubation use of racemic epinephrine | 1
44. Laryngeal lesions related to airway | 2
45. Number of arterial blood gas samples | 2
46. Tracheostomy | 1
47. Mean peak serum CPK level | 1
48. Serum CPK level at 24 hours | 2
49. Serum CPK level at 36 hours | 1
50. Serum CPK level at 48 hours | 1
51. Total myocardial infarction whether fatal or nonfatal | 8
52. Arrhythmias | 7
53. Ischemia incidence at 24 hours | 1
54. Ischemia incidence at 48 hours | 1
55. Ischemia: area under the curve | 1
56. Duration of ischemia | 1
57. Maximum ST depression | 1
58. Proportion of patients with ischemia; ischemic burden | 2
59. Number of patients with ischemia | 3
60. Incidence of angina | 1
61. Incidence of pulmonary edema, ischemic heart failure | 2
62. Pulmonary arterial pressure | 1
63. Pulmonary capillary wedge pressure | 1
64. Pulmonary vascular resistance index | 1
65. Right ventricular ejection fraction at time 1 | 1
66. Cardiac index after extubation | 1
67. Cardiac index 60 minutes following extubation | 2
68. Cardiac index 90 minutes following extubation | 1
69. Mean arterial pressure | 1
70. Pulmonary blood volume index at extubation | 1
71. Pulmonary blood volume index 60 minutes after extubation | 1
72. Pulmonary blood volume index 90 minutes after extubation | 1
73. Extravascular lung water at extubation | 1
74. Extravascular lung water at 60 minutes after extubation | 1
75. Extravascular lung water at 90 minutes after extubation | 1
76. Nosocomial pneumonia | 4
77. Nasal abrasion | 1
78. Respiratory quotient | 1
79. Spontaneous breathing for 3 hours | 1
Outcome Measurements | No. of Studies
Minor Outcomes
80. minute ventilation during weaning | 2
81. cumulative duration of mechanical support over 12-day study period | 1
82. right ventricular end systolic volume (RVESV) | 1
83. right ventricular end diastolic volume (RVEDV) | 1
84. need to resume controlled ventilation | 2
85. change in PaCO_2_ | 1
86. change In PaO_2_ | 1
87. time on ventilator from commencement of feeding to successful | 1
88. change in alveolar-arterial oxygen difference (AaDO_2_) | 1
89. change in vital capacity | 1
90. change in maximal inspiratory pressure | 1

Evidence Table 6. Methodologic characteristics of randomized trials, grouped according to intervention type

Studies Comparing Alternative Discontinuation Assessment Strategies
Author (year) | ICU Population | Diagnoses | Method of Randomization | Concealment | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Feeley (1975) | 25 patients in acute respiratory failure in a medical-surgical ICU | COPD, pneumonia, post-op, cardiac bypass surgery, cardiac valve surgery, infant RDS | Not reported | Not reported | Yes | Yes | No
Hastings (1980) | 18 good-risk, stable cardiac surgery patients in a CVICU | Cardiac bypass surgery, cardiac valve surgery | Not clearly reported | Not reported | Yes | No | No
Jones (1991) | 106 patients in a medical, surgical ICU in a tertiary care hospital | COPD, asthma, pneumonia, CHF, neurological, post-op, airway protection | Not clearly reported | Sealed unspecified envelopes | No | Yes | No
Abalos (1992) | 62 high-risk postoperative patients undergoing weaning in a surgical ICU in a tertiary care hospital | Post-op, unclear | Not reported | Not reported | No | No | No
Schirmer (1994) | 22 patients following coronary artery bypass grafting in a CVICU in a tertiary care hospital | Cardiac bypass surgery | Not reported | Not reported | Yes | No | No
Bailey (1995) | 80 adult patients scheduled to undergo primary aortocoronary bypass in a CVICU | Cardiac bypass surgery | Randomization table | Not reported | Yes | Yes | No
Esteban (1997) | 484 patients in a medical, surgical, ICU in a tertiary care hospital | COPD, pneumonia, CHF, acute lung injury, neurological, post-op, neuromuscular, trauma | Randomization table | Sealed opaque envelopes | Yes | Yes | Yes
Esteban (1999) | 526 patients in a medical and surgical ICU in a tertiary care hospital | COPD, pneumonia, CHF, acute lung injury, post-op, neuromuscular, trauma | Randomization table | Sealed opaque envelopes | Yes | Yes | Yes
Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support
Author (year) | ICU Population | Diagnoses | Method of Randomization | Concealment | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Brochard (1994) | 109 patients ventilated >24 hours and recovered from the acute phase of their disease in a medical-surgical ICU | COPD, CHF, post-op, neurological, neuromuscular | Not clearly reported | Sealed envelopes | Yes | Yes | No
Jounieaux (1994) | 19 COPD patients requiring mechanical ventilation for acute respiratory failure in a medical ICU | COPD | Not reported | Not reported | Yes | Yes | No
Esteban (1995) | 130 patients in a medical, surgical ICU in a tertiary care hospital | COPD, pneumonia, CHF, acute lung injury, post-op, neurological, neuromuscular, trauma | Randomization table | Sealed opaque envelopes | Yes | Yes | No
Nava (1998) | 50 intubated patients in a respiratory ICU | COPD | Not clearly reported | Sealed opaque envelopes | No | Yes | Yes
Girault (1999) | 33 patients in a medical ICU in a tertiary care hospital | COPD | Not clearly reported | Not reported | Yes | Yes | No
Studies Comparing Alternative Ventilation Modes for Weans Lasting Less than 48 Hours
Chopin (1989) | 42 adult patients with >4 days of controlled ventilation in a medical ICU | COPD | Randomization table | Not reported | Yes | Yes | No
Davis (1989) | 40 patients with > 24 hours of ventilation in a medical ICU | COPD, pneumonia | Not reported at all | Not reported | Yes | No | No
Esen (1992) | 40 mechanically ventilated patients with thorax injury in a trauma ICU in a tertiary care hospital | Trauma | Randomization method not clearly reported | Not reported | Yes | No | No
Studies Comparing Weaning Protocols to Physician-Directed Weaning
Strickland (1993) | 15 patients with complex medical problems who had required prolonged mechanical ventilation in medical ICU in a tertiary care hospital | COPD, asthma, pneumonia, CHF, acute lung injury, hemodynamic instability, neurological, post-op, cardiac valve surgery, trauma | Randomization table | Sealed unspecified envelopes | Yes | No | No
Ely (1996) | 300 patients in a medical ICU, CCU in a tertiary care hospital | COPD, asthma, pneumonia, CHF, neurological, acute lung injury | Randomization table | Concealed by sealed opaque envelopes | Yes | No | No
Kollef (1997) | 357 patients requiring mechanical ventilation in a medical, surgical ICU in a tertiary care hospital | COPD, asthma, pneumonia, acute lung injury, hemodynamic instability, post-op, trauma | Coin flip | Sealed opaque envelopes | Yes | Yes | No
Studies Comparing Early vs Late Extubation Follwing Cardiac Surgery (Anesthesia Intervention)
Author (year) | ICU Population | Diagnoses | Method of Randomization | Concealment | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Cheng (1996) | 120 elective coronary artery bypass grafting patients | Cardiac bypass | Randomization table | Not reported | No | Yes | No
Berry (1998) | 98 patients with elective coronary artery bypass grafting | Cardiac bypass | Randomization table | Not reported | No | Yes | No
Michalopoulos (1998) | 144 patients with elective coronary artery bypass grafting | Cardiac bypass | Not clearly reported | Not reported | No | Yes | No
Silbert (1998) | 100 patients with elective coronary artery bypass grafting | Cardiac bypass | Randomization table | Unclear | Yes | No | No
Engoren (1998) | 70 patients in a CVICU in a tertiary care hospital | Cardiac bypass | Randomization table | Not reported | Yes | Yes | No
Studies Comparing Early vs Late Extubation Following Cardiac Surgery (ICU Intervention)
Quasha (1980) | 38 patients with coronary artery bypass grafting | Cardiac bypass | Not reported | Not reported | Yes | Yes | No
Shackford (1981) | 35 patients undergoing aortic reconstruction in a tertiary care ICU | Aortic reconstruction | Not clearly reported | Not reported | No | Yes | No
Tempe (1995) | 100 patients undergoing elective closed mitral valvotomy | Mitral valve surgery | Not clearly reported | Not reported | Yes | Yes | No
Reyes (1997) | 404 open heart surgery patients | COPD, CHF, cardiac bypass surgery, cardiac valve surgery | Randomization table | Not reported | Yes | Yes | Yes
Dumas (1999) | 47 patients in a CVICU in a tertiary care hospital | Hemodynamic instability, cardiac bypass surgery | Not clearly reported | Not reported | No | Yes | No
Pediatric Studies of Corticosteroids to Prevent Postextubation Airway Complications
Author (year) | ICU Population | Diagnoses | Method of Randomization | Concealment | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Tellez (1991) | 153 patients requiring airway stabilization and mechanical ventilation in a pediatric ICU in a children's hospital | Asthma, cardiac bypass surgery, trauma | Not clearly reported | Not reported | No | No | No
Anene (1996) | 66 children <5 years, intubated and mechanically ventilated for >48 hours, in a tertiary care pediatric ICU | Pneumonia, post-op, neurological, congenital heart disease | Randomization table | Not reported | No | Yes | Yes
Harel (1997) | 26 tertiary care, pediatric ICU patients who had failed extubation with postextubation stridor | Asthma, pneumonia, acute lung injury, post-operative, neurological, infant RDS, trauma | Not clearly reported | Sealed envelopes | No | No | No
Adult Studies of Corticosteroids to Prevent Postextubation Airway Complications
Gaussorgues (1987) | 276 mechanically ventilated patients in an ICU | Pneumonia, hemodynamic instability, post-op, neurological | Not reported | Not reported | No | No | No
Darmon (1992) | 700 patients >15 years who had undergone tracheal intubation in an ICU | Hemodynamic instability, neurological, post-op | Randomization table | Sealed envelopes | No | No | No
Ho (1996) | 77 patients >14 years of age, who had undergone tracheal intubation for more than 24 hours in a tertiary care medical-surgical ICU | Hemodynamic instability, post-op, neurological, trauma | Randomization table | Not reported | No | No | No
Chaney (1998) | 60 patients in a CVICU in a tertiary care hospital | Cardiac bypass surgery | Not clearly reported | Not reported | No | Yes | No
Studies of Enteral Nutrition
Author (year) | ICU Population | Diagnoses | Method of Randomization | Concealment | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
al-Saady (1989) | 20 patients in a setting that was not described | COPD, pneumonia, acute lung injury, hemodynamic instability, post-op, trauma | Not clearly reported | Not reported | Yes | Yes | No
Vandenberg (1994) | 32 adult, ventilator- dependent patients in a tertiary care medical ICU | COPD, pneumonia, neurological | Randomization table | Not reported | Yes | No | No
Miscellaneous Studies
Niehoff (1988) | 24 mechanically ventilated patients in a tertiary care surgical ICU | Cardiac bypass surgery, cardiac valve surgery | Not clearly reported | Not reported | Yes | No | No
Holliday (1990) | 40 patients in a medical surgical CVICU | COPD, pneumonia, hemodynamic instability, post-op, neurological, cardiac bypass surgery, trauma | Randomization table | Not reported | No | No | No
Gust (1996) | 75 patients following coronary artery bypass grafting in a CVICU in a tertiary care hospital | Cardiac bypass surgery | Not clearly reported | Not reported | Yes | No | No
Pichard (1996) | 20 patients requiring 7 days of mechanical ventilation for acute respiratory failure in setting that was not described | COPD, pneumonia, acute lung injury, trauma | Not clearly reported | Not reported | Yes | Yes | No
Jiang (1999) | 93 patients in a tertiary care hospital | COPD, CHF, neurological | Not clearly reported | Not reported | No | Yes | Yes
Lee (1998) | 76 patients in a post-anesthesia recovery room in a tertiary care hospital | postoperative | Not clearly reported | Not reported | No | Yes | No

Evidence Table 7. Results of individual randomized trials

Studies Comparing Alternative Discontinuation Assessment Strategies
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Feeley (1975) int 1: CPAP 5 cm H_2_O int 2: T-Piece | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Feeley (1975) int 1: CPAP 5 cm H_2_O int 2: T-Piece | Change in PaCO_2_ Duration of Weaning Change in AaDO_2_ Change in Vital Capacity Change in MIP | 1: 9.38 ± 8.80 2: 8.69 ± 5.34 1: 31.43 ± 68.30 2: 5.20 ± 4.27 1: 10.00 ± 76.21 2: 102.00 ± 126.19 1: 258.00 ± 374.12 2: -8.00 ± 198.31 1: -15.00 ± 17.32 2: -1.00 ± 10.82 | 0.69 (-4.96, 6.34) 26.23 (-10.73, 63.19) -92.00 (-174.62, -9.38) 266.00 (33.96, 498.04) -14.00 (-25.22, -2.78) | 0.81 0.16 0.03 0.02 0.01
Feeley (1975) int 1: CPAP 5 cm H_2_O int 2: T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Feeley (1975) int 1: CPAP 5 cm H_2_O int 2: T-Piece | ICU Mortality Nonextubation Reintubation Combined Endpoint: Nonextubation + Reintubation | 1: 2/12 2: 1/13 1: 4/12 2: 2/13 1: 1/8 2: 0/11 1: 5/12 2: 2/13 | 1.80 (0.28, 11.71) 1.94 (0.51, 7.43) 4.06 (0.19, 87.91) 2.38 (0.66, 8.56) | 0.54 0.33 0.37 0.19
Hastings (1980) int 1: IMV 4 bpm Plus CPAP 5 cm H_2_O int 2: CPAP 5 cm H_2_O | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Hastings (1980) int 1: IMV 4 bpm Plus CPAP 5 cm H_2_O int 2: CPAP 5 cm H_2_O | Duration of Mechanical Ventilation Duration of Weaning | 1: 28.32 ± 3.18 2: 24.40 ± 7.18 1: 2.82 ± 1.10 2: 2.50 ± 1.15 | 3.92 (-1.45, 9.29) 0.32 (-0.73, 1.37) | 0.15 0.55
Hastings (1980) int 1: IMV 4 bpm Plus CPAP 5 cm H_2_O int 2: CPAP 5 cm H_2_O | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Hastings (1980) int 1: IMV 4 bpm Plus CPAP 5 cm H_2_O int 2: CPAP 5 cm H_2_O | Reintubation | 1: 0/8 2: 0/10 | 1.00 | 1.00
Jones (1991) int 1: CPAP 5 cm H_2_O int 2: T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Jones (1991) int 1: CPAP 5 cm H_2_O int 2: T-Piece | Nonextubation Reintubation Combined Endpoint: Nonextubation + Reintubation | 1: 3/54 2: 2/52 1: 3/51 2: 2/50 1: 6/54 2: 4/52 | 1.35 (0.28, 6.54) 1.37 (0.28, 6.64) 1.39 (0.44, 4.35) | 0.71 0.69 0.57
Abalos (1992) int 1: CPAP 10 cm H_2_O int 2: CPAP 5 cm H_2_O int 3: T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Abalos (1992) int 1: CPAP 10 cm H_2_O int 2: CPAP 5 cm H_2_O int 3: T-Piece | Cardiac Ischemia | 1: 0/19 2: 2/22 3: 3/21 | 1 vs. 3: 0.16 (0.01, 2.86) 2 vs. 3: 0.68 (0.15, 3.09) 1 vs. 2: 0.23 (0.01, 4.52) | 0.21 0.62 0.33
Schirmer (1994) int 1: PS10 cm H_2_O + PEEP 5 cm H_2_O (I:E = 1:2 using BiPAP System) int 2: PS10 + PEEP5 (I:E Variable) | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Schirmer (1994) int 1: PS10 cm H_2_O + PEEP 5 cm H_2_O (I:E = 1:2 using BiPAP System) int 2: PS10 + PEEP5 (I:E Variable) | Right Ventricular End Systolic Volume Right Ventricular End Diastolic Volume Tidal Volume Respiratory Rate PaO_2_ PaCO_2_ Mean Pulmonary Arterial Pressure Pulmonary Capillary Wedge Pressure Pulmonary Vascular Resistance Index Right Ventricular Ejection Fraction Cardiac Index Mean Arterial Pressure | 1: 92.20 ± 36.30 2: 77.20 ± 30.40 1: 176.00 ±48.50 2: 161.60 ± 43.30 1: 550.00 ±155.00 2: 615.00 ± 160.00 1: 13.80 ± 2.80 2: 13.80 ± 8.10 1: 97.60 ± 14.60 2: 97.80 ± 17.10 1: 41.70 ± 3.20 2: 41.90 ± 3.20 1: 20.60 ± 5.00 2: 19.30 ± 4.20 1: 12.20 ± 3.90 2: 12.10 ± 3.90 1: 206.00 ± 55.00 2: 181.00 ± 61.00 1: 46.00 ± 11.90 2: 51.80 ± 12.40 1: 3.10 ± 0.70 2: 3.40 ± 0.80 1: 76.30 ± 11.60 2: 74.60 ± 10.10 | 15.00 14.80 -65.00 0.00 -0.20 -0.20 1.30 (0.21, 2.39) 0.10 25.00 (1.10, 48.90) -5.80 (-9.26, -2.34) -0.30 1.70 | >0.05 >0.05 >0.05 >0.05 >0.05 >0.05 0.02 >0.05 0.04 0.001 >0.05 >0.05
Bailey (1995) int 1: CPAP 10 cm H_2_O int 2: CPAP 5 cm H_2_O int 3: T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Bailey (1995) int 1: CPAP 10 cm H_2_O int 2: CPAP 5 cm H_2_O int 3: T-Piece | Nonextubation | 1: 0/26 2: 0/27 3: 0/27 | 1 vs. 3: 1.00 2 vs. 3: 1:00 1 vs. 2: 1:00 | 1.00 1.00 1.00
Esteban (1997) int 1: Pressure Support 7 cm H_2_O int 2: T-Piece | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Esteban (1997) int 1: Pressure Support 7 cm H_2_O int 2: T-Piece | ICU Length of Stay Hospital Length of Stay | 1: 12.0 ± xx ^1^ 2: 10.0 ± xx 1: 28.0 ± xx 2: 24.0 ± xx | 2.00 4.00 | 0.33 0.33
Esteban (1997) int 1: Pressure Support 7 cm H_2_O int 2: T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Esteban (1997) int 1: Pressure Support 7 cm H_2_O int 2: T-Piece | ICU Mortality Hospital Mortality Nonextubation Reintubation Combined Endpoint: Nonextubation + Reintubation | 1: 12/205 2: 17/192 1: 41/238 2: 40/246 1: 33/238 2: 54/246 1: 38/205 2: 36/192 1: 71/238 2: 90/246 | 0.67 (0.33, 1.35) 1.06 (0.71, 1.57) 0.64 (0.43, 0.94) 0.99 (0.66, 1.49) 0.89 (0.67, 1.20) | 0.26 0.78 0.02 0.95 0.45
Esteban (1999) int 1: T-Piece (30 minutes) int 2: T-Piece (120 minutes) | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Esteban (1999) int 1: T-Piece (30 minutes) int 2: T-Piece (120 minutes) | ICU Length of Stay Hospital Length of Stay | 1: 10.00 ± 9.00 2: 12.00 ± 10.50 1: 22.00 ± 13.50 2: 27.00 ± 19.50 | -2.00 (-3.67, -0.33) -5.00 (-7.85, -2.15) | 0.02 <0.01
Esteban (1999) int 1: T-Piece (30 minutes) int 2: T-Piece (120 minutes) | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Esteban (1999) int 1: T-Piece (30 minutes) int 2: T-Piece (120 minutes) | ICU Mortality Hospital Mortality Nonextubation Reintubation Combined Endpoint: Nonextubation + Reintubation | 1: 34/270 2: 22/256 1: 51/270 2: 40/256 1: 33/270 2: 40/256 1: 32/237 2: 29/216 1: 65/270 2: 69/256 | 1.45 (0.88, 2.40) 1.21 (0.83, 1.75) 0.78 (0.51, 1.20) 1.08 (0.63, 1.60) 0.89 (0.67, 1.20) | 0.14 0.33 0.26 0.99 0.45
Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Brochard (1994) int 1: Pressure Support (± CPAP) int 2: Synchonized IMV (± CPAP) int 3: Multiple Daily T-Piece | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Brochard (1994) int 1: Pressure Support (± CPAP) int 2: Synchonized IMV (± CPAP) int 3: Multiple Daily T-Piece | ICU Length of Stay (d) Duration of Weaning (h) | 1: 17.50 ± 10.20 2: 26.80 ± 19.00 3: 28.90 ± 17.70 1: 136.80 ± 88.80 2: 237.60 ± 196.80 3: 204.00 ± 199.20 | 1 vs. 3: -11.40 (-18.73, -4.07) 2 vs. 3: -2.10 (-10.51, 6.31) 1 vs. 2: -9.30 (-16.88, -1.72) 1 vs. 3: -67.20 (-143.29, 8.89) 2 vs. 3: 33.60 (-54.69, 121.89) 1 vs. 2: -100.80 (-175.09, -26.51) | <0.01 0.62 0.02 0.08 0.46 0.01
Brochard (1994) int 1: Pressure Support (± CPAP) int 2: Synchonized IMV (± CPAP) int 3: Multiple Daily T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Brochard (1994) int 1: Pressure Support (± CPAP) int 2: Synchonized IMV (± CPAP) int 3: Multiple Daily T-Piece | ICU mortality Reintubation at 48 h Nonextubation at 21 d Pulmonary Edema or Ischemic Heart Failure Nosocomial Pneumonia Combined Endpoint: Nonextubation + Reintubation | 1: 4/31 2: 10/43 3: 8/35 1: 3/27 2: 6/31 3: 3/23 1: 4/31 2: 12/43 3: 12/35 1: 1/31 2: 3/43 3: 1/35 1: 0/31 2: 3/43 3: 3/35 1: 7/31 2: 18/43 3: 15/35 | 1 vs. 3: 0.60 (0.21, 1.68) 2 vs. 3: 1.01 (0.46, 2.22) 1 vs. 2: 0.59 (0.22, 1.62) 1 vs. 3: 0.85 (0.22, 3.68) 2 vs. 3: 1.39 (0.42, 4.53) 1 vs. 2: 0.62 (0.19, 204) 1 vs. 3: 0.41 (0.15, 1.06) 2 vs. 3: 0.82 (0.43, 1.56) 1 vs. 2: 0.50 (0.19, 1.32) 1 vs. 3: 1.13 (0.12, 10.29) 2 vs. 3: 1.90 (0.30, 12.24) 1 vs. 2: 0.59 (0.09, 3.79) 1 vs. 3: 0.16 (0.01, 3.00) 2 vs. 3: 0.82 (0.20, 3.36) 1 vs. 2: 0.20 (0.01, 3.69) 1 vs. 3: 0.55 (0.26, 1.13) 2 vs. 3: 0.97 (0.59, 1.62) 1 vs. 2: 0.56 (0.27, 1.14) | 0.33 0.98 0.31 0.82 0.59 0.43 0.07 1.54 0.16 0.92 0.50 0.58 0.22 0.78 0.28 0.10 0.92 0.11
Jounieaux (1994) int 1: Synchronized IMV + Pressure Support (No CPAP) int 2: Synchronized IMV (No CPAP) | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Jounieaux (1994) int 1: Synchronized IMV + Pressure Support (No CPAP) int 2: Synchronized IMV (No CPAP) | Duration of Weaning (h) | 1: 100.80 ± 19.20 2: 127.20 ± 24.00 | -26.40 (-45.84, -6.96) | 0.01
Jounieaux (1994) int 1: Synchronized IMV + Pressure Support (No CPAP) int 2: Synchronized IMV (No CPAP) | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Jounieaux (1994) int 1: Synchronized IMV + Pressure Support (No CPAP) int 2: Synchronized IMV (No CPAP) | Nonextubation at 1 week Reintubation at 72 h | 4: 0/10 5: 0/9 1: 0/10 2: 2/9 | 1.00 0.18 (0.01, 3.31) | 1.00 0.25
Jounieaux (1994) int 1: Synchronized IMV + Pressure Support (No CPAP) int 2: Synchronized IMV (No CPAP) | Combined Endpoint: Nonextubation + Reintubation | 1: 0/10 2: 2/9 | 0.18 (0.01, 3.31) | 0.25
Esteban (1995) int 1: Pressure Support (± CPAP) int 2: Synchronized (± CPAP) int 3: Multiple Daily T-Piece int 4: Once Daily T-Piece | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Esteban (1995) int 1: Pressure Support (± CPAP) int 2: Synchronized (± CPAP) int 3: Multiple Daily T-Piece int 4: Once Daily T-Piece | Duration of Weaning (h) | 1: 96.00 ± 180.00 2: 120.00 ± 144.00 3: 72.00 ± 72.00 4: 72.00 ± 90.00 | 1 vs. 4: 24.00 (-45.74, 93.74) 2 vs. 4: 48.00 (-12.34, 108.34) 3 vs. 4: 0.00 (-39.81, 39.81) 1 vs. 3: 24.00 (-41.69, 89.69) 2 vs. 3: 48.00 (-7.65, 103.65) 1 vs. 2: -24.00 (-104.31, 56.31) | 0.50 0.12 1.00 0.47 0.09 0.56
Esteban (1995) int 1: Pressure Support (± CPAP) int 2: Synchronized (± CPAP) int 3: Multiple Daily T-Piece int 4: Once Daily T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Esteban (1995) int 1: Pressure Support (± CPAP) int 2: Synchronized (± CPAP) int 3: Multiple Daily T-Piece int 4: Once Daily T-Piece | Nonextubation at 14 d Reintubation at 48 h Combined Endpoint: Nonextubation + Reintubation | 1: 4/37 2: 5/29 3: 1/33 4: 1/31 1: 7/33 2: 4/24 3: 5/32 4: 4/30 1: 11/37 2: 9/29 3: 6/33 4: 5/31 | 1 vs. 4: 2.53 (0.42, 15.09) 2 vs. 4: 3.91 (0.69, 22.18) 3 vs. 4: 0.94 (0.10, 8.59) 1 vs. 3: 2.68 (0.45, 16.06) 2 vs. 3: 4.16 (0.73, 23.61) 1 vs. 2: 0.65 (0.20, 2.04) 1 vs. 4: 1.52 (0.53, 4.40) 2 vs. 4: 1.24 (0.38, 4.10) 3 vs. 4: 1.15 (0.37, 3.61) 1 vs. 3: 1.32 (0.49, 3.56) 2 vs. 3: 1.08 (0.35, 3.35) 1 vs. 2: 1.23 (0.43, 3.50) 1 vs. 4: 1.76 (1.71, 4.32) 2 vs. 4: 1.84 (0.73, 4.64) 3 vs. 4: 1.11 (0.40, 3.10) 1 vs. 3: 1.58 (0.68, 3.67) 2 vs. 3: 1.66 (0.70, 3.95) 1 vs. 2: 0.95 (0.70, 1.94) | 0.31 0.12 0.96 0.28 0.11 0.46 0.44 0.72 0.81 0.58 0.89 0.70 0.22 0.19 0.84 0.29 0.25 0.89
Nava (1998) int 1: Extubation and Noninvasive Positive Pressure Ventilation int 2: Pressure Support (± CPAP) | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Nava (1998) int 1: Extubation and Noninvasive Positive Pressure Ventilation int 2: Pressure Support (± CPAP) | ICU Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 15.10 ± 5.40 2: 24.00 ±13.70 1: 244.80 ± 163.20 2: 398.40 ± 283.20 | -8.90 (-14.67, -3.13) -153.60 (-281.73, -25.47) | <0.01 0.02
Nava (1998) int 1: Extubation and Noninvasive Positive Pressure Ventilation int 2: Pressure Support (± CPAP) | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Nava (1998) int 1: Extubation and Noninvasive Positive Pressure Ventilation int 2: Pressure Support (± CPAP) | 60-day Mortality Nosocomial Pneumonia Nasal Abrasion Patients Requiring Long Term Ventilation | 1: 2/25 2: 7/25 1: 0/25 2: 7/25 1: 14/25 2: 0/25 1: 1/25 2: 2/25 | 0.33 (0.09, 1.25) 0.07 (0.00, 1.11) 29.00 (1.83, 460.63) 0.60 (0.09, 4.22) | 0.10 0.06 0.02 0.61
Girault (1999) int 1: Noninvasive Ventilation int 2: Pressure Support | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Girault (1999) int 1: Noninvasive Ventilation int 2: Pressure Support | ICU Length of Stay Hospital Length of Stay Duration of Intubation | 1: 12.35 ± 6.82 2: 14.06 ± 7.54 1: 27.12 ± 14.33 2: 27.69 ± 13.09 1: 4.56 ± 1.85 2: 7.69 ± 3.79 | -1.71 (-6.61, -3.19) -0.57 (-9.95, 8.81) -3.13 (-5.15, -1.11) | 0.49 0.91 <0.01
Girault (1999) int 1: Noninvasive Ventilation int 2: Pressure Support | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Girault (1999) int 1: Noninvasive Ventilation int 2: Pressure Support | Hospital Mortality 90-Day Mortality Reintubation Arrhythmias Nosocomial Pneumonia | 1: 0/17 2: 2/16 1: 0/17 2: 2/16 1: 4/17 2: 4/16 1: 0/17 2: 1/16 1: 1/17 2: 1/16 | 0.19 (0.01, 3.64) 0.19 (0.01, 3.64) 0.94 (0.31, 2.89) 0.31 (0.01, 7.18) 0.94 (0.11, 8.18) | 0.27 0.27 0.92 0.47 0.96
Studies Comparing Alternative Ventilation Modes for Weans Lasting Less Than 48 Hours
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Chopin (1989) int 1: CO_2_ Mandatory Ventilation (No CPAP) int 2: Intermittent Mandatory Ventilation (No CPAP) int 3: Multiple Daily T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Chopin (1989) int 1: CO_2_ Mandatory Ventilation (No CPAP) int 2: Intermittent Mandatory Ventilation (No CPAP) int 3: Multiple Daily T-Piece | Nonextubation at 24 h Reintubation Combined Endpoint: Nonextubation + Reintubation | 1: 1/14 2: 9/14 1: 4/14 1: 0/13 2: 0/5 3: 0/10 1: 1/14 2: 9/14 3: 4/14 | 1 vs. 3: 0.33 (0.06, 1.82) 2 vs. 3: 2.11 (0.90, 4.96) 1 vs. 2: 0.16 (0.03, 0.75) 1 vs. 3: 1:00 2 vs. 3: 1:00 1 vs. 2: 1:00 1 vs. 3: 0.33 (0.06, 1.82) 2 vs. 3: 2.11 (0.90, 4.96) 1 vs. 2: 0.16 (0.03, 0.75) | 0.20 0.09 0.02 1.00 1.00 1.00 0.20 0.09 0.02
Davis (1989) int 1: IMV (No CPAP) int 2: Mandatory Minute Ventilation (No CPAP) | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Davis (1989) int 1: IMV (No CPAP) int 2: Mandatory Minute Ventilation (No CPAP) | Duration of Successful Weaning | 1: 33.30 ± 21.00 2: 4.75 ± 1.50 | 28.55 (19.77, 37.33) | <0.01
Davis (1989) int 1: IMV (No CPAP) int 2: Mandatory Minute Ventilation (No CPAP) | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Davis (1989) int 1: IMV (No CPAP) int 2: Mandatory Minute Ventilation (No CPAP) | Nonextubation | 1: 5/18 2: 5/22 | 1.22 (0.44, 3.34) | 0.70
Esen (1992) int 1: Pressure Support (No CPAP) int 2: Intermittent Mandatory Ventilation (No CPAP) | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Esen (1992) int 1: Pressure Support (No CPAP) int 2: Intermittent Mandatory Ventilation (No CPAP) | Duration of Mechanical Ventilation/Day Duration of Weaning/Day | 1: 19.10 ± 2.30 2: 22.40 ± 3.10 1: 6.30 ± 3.10 2: 9.90 ± 2.70 | -3.30 (-4.99, -1.61) -3.60 (-5.40, -1.80) | <0.01 <0.01
Esen (1992) int 1: Pressure Support (No CPAP) int 2: Intermittent Mandatory Ventilation (No CPAP) | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Esen (1992) int 1: Pressure Support (No CPAP) int 2: Intermittent Mandatory Ventilation (No CPAP) | Nonextubation at 48 h Reintubation at 48 h Combined Endpoint: Nonextubation + Reintubation | 1: 3/20 2: 5/20 1: 0/17 2: 0/15 1: 3/20 2: 5/20 | 0.64 (0.19, 2.10) 1.00 0.64 (0.19, 2.10) | 0.46 1.0 0.46
Studies Comparing Weaning Protocols to Physician-directed Weaning
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Strickland (1993) int 1: Computer-directed Wean int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Strickland (1993) int 1: Computer-directed Wean int 2: Physician-directed Wean | Duration of Weaning (h) | 1: 18.70 ± 5.90 2: 25.60 ± 5.60 | -6.90 (-12.88, -0.92) | 0.02
Strickland (1993) int 1: Computer-directed Wean int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Strickland (1993) int 1: Computer-directed Wean int 2: Physician-directed Wean | Nonextubation Reintubation Combined Endpoint: Nonextubation + Reintubation | 2: 2/9 3: 4/6 1: 0/7 2: 2/2 1: 2/49 2: 6/6 | 0.38 (0.12, 1.24) 0.07 (0.00, 0.97) 0.26 (0.09, 0.76) | 0.11 0.55 0.01
Ely (1996) int 1: Daily Screening ± T-Piece Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | difference in Means (95% CI)
Ely (1996) int 1: Daily Screening ± T-Piece Protocol int 2: Physician-directed Wean | ICU Length of Stay (d) Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) Duration of Weaning (h) | 1: 8.00 ± 10.50 2: 9.00 ± 8.25 1: 14.00 ± 12.75 2: 15.50 ± 18.00 1: 108.00 ± 126.00 2: 144.00 ± 144.00 1: 24.00 ± 36.00 2: 72.00 ± 90.00 | -1.00 (-3.14, 1.14) -1.50 (-5.03, 2.03) -36.00 (-66.64, -5.36) -48.00 (-63.55, -32.45) | 0.36 0.41 0.02 <0.01
Ely (1996) int 1: Daily Screening ± T-Piece Protocol int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Ely (1996) int 1: Daily Screening ± T-Piece Protocol int 2: Physician-directed Wean | Mechanical Ventilation for >21 days Self-extubation Reintubation | 1: 9/149 2: 20/151 1: 2/149 2: 5/151 1: 5/149 2: 12/151 | 0.47 (0.23, 0.98) 0.46 (0.11, 2.02) 0.45 (0.17, 1.18) | 0.04 0.30 0.11
Kollef (1997) int 1: Protocol by Nurse and Respiratory Therapist int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Kollef (1997) int 1: Protocol by Nurse and Respiratory Therapist int 2: Physician-directed Wean | Hospital Length of Stay (d) Duration of Intubation (h) | 1: 12.70 ± 9.40 2: 14.20 ±11.70 1: 35.00 ± 74.25 2: 44.00 ± 141.00 | -1.50 (-3.70, 0.70) -9.00 (-32.36, 14.36) | 0.18 0.45
Kollef (1997) int 1: Protocol by Nurse and Respiratory Therapist int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Kollef (1997) int 1: Protocol by Nurse and Respiratory Therapist int 2: Physician-directed Wean | Hospital Mortality Reintubation Requiring Mechanical Ventilation >7 d Combined Endpoint: Nonextubation + Reintubation | 1: 40/179 2: 42/178 1: 23/158 2: 18/147 1: 21/179 2: 31/178 1: 44/179 2: 49/178 | 0.95 (0.65, 1.38) 1.18 (0.67, 2.08) 0.68 (0.41, 1.13) 0.89 (0.63, 1.27) | 0.78 0.56 0.13 0.53
Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (Anesthesia intervention)
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Cheng (1996a) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Cheng (1996a) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) 24-hour CPK 48-hour CPK Duration of Ischemia | 1: 29.20 ± 11.70 2: g30.90 ± 12.80 1: g7.00 ± 2.50 2: g8.20 ± 3.50 1: g4.10 ± 1.10 2: g18.90 ± 1.40 1: g14.00 ± xx ^1^ 2: g18.00 ± xx 1: g12.00 ± xx 2: g15.00 ± xx 1: g156.60 ± 143.20 2: g107.90 ± 119.50 | -1.70 (-6.46, 3.06) -1.20 (-2.38, -0.02) -14.80 (-15.29, -14.31) -4.00 -3.00 48.70 (1.51, 95.89) | 0.48 0.05 <0.01 <0.05 <0.05 0.04
Cheng (1996a) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Cheng (1996a) int 1: Early Extubation int 2: Late Extubation | 30-day Mortality Reintubation Nonextubation Myocardial Infarction 24-hour Ischemic Incidence 48-hour Ischemic Incidence Combined Endpoint: Nonextubation + Reintubation | 3: 0/60 4: 3/60 1: 1/51 2: 0/51 1: 9/60 2: 9/60 1: 0/60 2: 4/60 1: 10/51 2: 3/51 1: 3/51 2: 2/51 1: 10/60 2: 9/60 | 0.14 (0.01, 2.71) 3.00 (0.13, 71.94) 1.00 (0.44, 2.28) 0.11 (0.01, 2.02) 3.00 (0.95, 9.44) 1.40 (0.29, 6.77) 1.11 (0.50, 2.46) | 0.19 0.50 1.00 0.14 0.06 0.68 0.81
Berry (1998) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Berry (1998) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) 24-hour CPK 48-hour CPK Ischemia (Area Under ROC) Maximum ST Depression Ischemic Burden | 1: 48.00 ± 0.00 2: 48.00 ± 36.00 1: 8.00 ± 4.50 2: 8.00 ± 2.25 1: 1.83 ± 3.15 2: 12.62 ± 9.30 1: 56.00 ± 188.25 2: 57.00 ± 42.00 1: 42.00 ± 126.75 2: 40.00 ± 110.25 1: 10.00 ± 29.03 2: 8.23 ± 32.10 1: 1.28 ± 0.98 2: 1.30 ± 0.45 1: 5.65 ± 25.35 2: 4.50 ± 19.95 | 0.00 (-10.76, 10.76) 0.00 (-1.52, 1.52) -10.79 (-13.73, -7.85) -1.00 (-59.31, 57.31) 2.00 (-48.55, 52.55) 1.77 (-11.23, 14.77) -0.02 (-0.34, 0.30) 1.15 (-8.56, 10.86) | 1.00 1.00 <0.01 0.97 0.94 0.79 0.90 0.82
Berry (1998) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Berry (1998) int 1: Early Extubation int 2: Late Extubation | ICU Mortality Hospital Mortality Myocardial Infarction Arrhythmias Ischemia | 1: 0/43 2: 2/42 1: 0/43 2: 2/42 1: 2/43 2: 2/42 1: 0/43 2: 0/42 1: 22/43 2: 17/42 | 0.20 (0.01, 3.95) 0.20 (0.01, 3.95) 0.98 (0.18, 5.36) 1.00 1.26 (0.79, 1.99) | 0.29 0.29 0.98 1.00 0.33
Michalopoulos (1998) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Michalopoulos (1998) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 16.08 ± 1.30 2: 23.04 ± 1.20 1: 7.30 ± 0.80 2: 8.40 ± 0.90 1: 7.30 ± 0.70 2: 11.60 ± 1.30 | -6.96 (-7.37, -6.55) -1.10 (-1.38, -0.82) -4.30 (-4.64, -3.96) | <0.01 <0.01 <0.01
Michalopoulos (1998) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Michalopoulos (1998) int 1: Early Extubation int 2: Late Extubation | Myocardial Infarction Arrhythmias Ischemia Reintubation Hospital Mortality | 1: 0/72 2: 0/72 1: 8/72 2: 9/72 1: 3/72 2: 4/72 1: 0/72 2: 0/72 1: 0/72 1: 0/72 | 1.00 0.89 (0.38, 2.13) 0.78 (0.20, 3.03) 1.00 1.00 | 1.00 0.80 0.72 1.00 100
Engoren (1998) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Engoren (1998) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 21.00± 6.00 2: 23.00± 9.00 1: 5.10 ± 1.80 2: 6.00 ± 3.00 1: 6.5± 3.4 2: 7.5 ± 4.2 | -2.00 (-5.58, 1.58) -0.90 (-2.06, 0.26) -61.00 (-168.00, 46.00) | 0.27 0.13 0.26
Engoren (1998) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Engoren (1998) int 1: Early Extubation int 2: Late Extubation | Hospital Mortality Reintubation Myocardial Infarction | 1: 0/35 2: 0/35 1: 0/35 2: 0/35 1: 0/35 2: 1/35 | 1.00 1.00 0.33 (0.01, 7.91) | 1.00 1.00 0.50
Silbert (1998) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95%CI)
Silbert (1998) int 1: Early Extubation int 2: Late Extubation | Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) Mean Total CPK | 1: 8.00 ± 19.50 2: 7.00 ± 11.25 1: 4.00 ± 11.25 2: 7.00 ± 12.68 1: 766.00 ± 428.00 2: 998.00 ± 551.00 | 1.00 (-5.90, 7.90) -3.00 (-8.27, 2.27) -232.00 (-449.86,-14.14) | 0.78 0.26 0.04
Silbert (1998) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Silbert (1998) int 1: Early Extubation int 2: Late Extubation | Hospital Mortality Reintubation Myocardial Infarction | 1: 1/38 2: 0/42 1: 0/38 2: 0/42 1: 0/38 2: 0/42 | 3.31 (0.14, 78.91) 1.00 1.00 | 0.46 1.00 1.00
Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (ICU Intervention)
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Quasha (1980) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Quasha (1980) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Duration of Mechanical Ventilation (h) | 1: 46.08 ± 12.00 2: 57.12 ± 29.04 1: 2.00 ± 2.00 2: 18.00 ± 3.00 | -11.04 (-26.24, 4.16) -16.00 (-17.71,-14.29) | 0.15 <0.01
Quasha (1980) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Quasha (1980) int 1: Early Extubation int 2: Late Extubation | Reintubation Myocardial Infarction Arrhythmias | 3: 1/18 4: 0/20 1: 0/18 2: 3/20 1: 4/18 2: 6/20 | 3.32 (0.14, 76.68) 0.16 (0.01, 2.86) 0.77 (0.28, 2.14) | 0.45 0.21 0.61
Shackford (1981) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Shackford (1981) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Duration of Mechanical Ventilation (h) | 1: 55.20 ± 9.90 2: 69.60 ± 20.36 1: 3.30 ± 2.06 2: 18.30 ± 2.12 | -14.40 (-25.11, -3.69) -15.00 (-16.39, -13.61) | 0.01 <0.01
Shackford (1981) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Shackford (1981) int 1: Early Extubation int 2: Late Extubation | ICU Mortality Reintubation | 1: 0/17 2: 0/18 1: 0/17 2: 0/18 | 1.00 1.00 | 1.00 1.00
Tempe (1995) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Tempe (1995) int 1: Early Extubation int 2: Late Extubation | Reintubation | 1: 0/50 2: 0/50 | 1.00 | 1.00
Reyes (1997) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Reyes (1997) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (h) Duration of Mechanical Ventilation (h) Duration of Intubation (h) | 1: 27.00 ± xx ^1^ 2: 44.00 ± xx 1: 8.52 ± xx 2: 19.00 ± xx 1: 10.00 ± xx 2: 21.00 ± xx | -17.00 -10.48 -11.00 | <0.01 <0.01 <0.01
Reyes (1997) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Reyes (1997) int 1: Early Extubation int 2: Late Extubation | 30-Day Mortality Reintubation ICU Discharge at 24 h | 1: 18/201 2: 15/203 1: 7/201 2: 2/203 1: 89/201 2: 62/203 | 1.21 (0.63, 2.30) 3.03 (0.73, 12.51) 1.45 (1.12, 1.87) | 0.57 0.13 0.01
Dumas (1999) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Dumas (1999) int 1: Early Extubation int 2: Late Extubation | Duration of Ventilation (h) | 1: 3.49 ± 2.21 2: 10.32 ± 1.75 | -6.83 (-7.96, -5.70) | <0.01
Pediatric Studies of Corticosteroids to Prevent Post-Extubation Airway Complications
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Tellez (1991) int 1: Steroids int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Tellez (1991) int 1: Steroids int 2: No Steroids | Reintubation Stridor | 1: 9/76 2: 4/77 1: 16/76 2: 23/77 | 2.14 (0.73, 6.27) 0.71 (0.41, 1.23) | 0.17 0.22
Anene (1996) int 1: Steriods int 2: No Steroids | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Anene (1996) int 1: Steriods int 2: No Steroids | Croup Score at 10 min Croup Score at 6 h Croup Score at 12 h Croup Score at 24 h | 1: 1.00 ± xx ^1^ 2: 2.00 ± xx 1: 0.00 ± xx 2: 1.00 ± xx 1: 0.00 ± xx 2: 0.50 ± xx 1: 0.00 ± xx 2: 0.00 ± xx | -1.00 -1.00 -0.50 0.00 | <0.01 <0.01 <0.01 >0.05
Anene (1996) int 1: Steriods int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Anene (1996) int 1: Steriods int 2: No Steroids | Reintubation Stridor at 10 min Stridor at 6 hr Stridor at 12 hr Stridor at 24 hr Racemic Epinephrine | 1: 0/31 2: 7/32 1: 14/31 2: 28/32 1: 8/31 2: 22/28 1: 2/31 2: 13/26 1: 1/31 2: 4/25 1: 4/31 2: 22/32 | 0.07 (0.00, 1.15) 0.52 (0.35, 0.78) 0.34 (0.19, 0.63) 0.16 (0.04, 0.54) 0.27 (0.05, 1.59) 0.21 (0.09, 0.50) | 0.06 <0.01 <0.01 <0.01 0.15 <0.01
Harel (1997) int 1: Steriods int 2: No Steroids | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Harel (1997) int 1: Steriods int 2: No Steroids | Stridor Score | 1: 5.08 ± 2.84 2: 6.18 ± 3.37 | -1.10 (-3.64, 1.44) | 0.40
Harel (1997) int 1: Steriods int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Harel (1997) int 1: Steriods int 2: No Steroids | Reintubation Tracheostomy | 1: 3/12 2: 5/11 1: 3/12 2: 0/11 | 0.59 (0.20, 1.71) 6.44 (0.37, 111.66) | 0.33 0.20
Adult Studies of Corticosteroids to Prevent Post-Extubation Airway Complications
Gaussorgues (1987) int 1: Steroids int 2: No Steroids | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Gaussorgues (1987) int 1: Steroids int 2: No Steroids | Duration of Mechanical Ventilation | 1: 312 ± 264 2: 384 ± 216 | -0.72 (-128.91,-15.09) | 0.01
Gaussorgues (1987) int 1: Steroids int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Gaussorgues (1987) int 1: Steroids int 2: No Steroids | Reintubation Laryngeal Lesions | 1: 4/138 2: 0/138 1: 4/138 2: 2/138 | 9.00 (0.49, 165.59) 1.80 (0.39, 8.30) | 0.14 0.45
Darmon (1992) int 1: Steroids int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Darmon (1992) int 1: Steroids int 2: No Steroids | Reintubation Laryngeal Lesions | 1: 2/327 2: 5/337 1: 11/327 2: 17/337 | 0.47 (0.11, 2.07) 0.68 (0.33, 1.40) | 0.32 0.29
Ho (1996) int 1: Steroids int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Ho (1996) int 1: Steroids int 2: No Steroids | Reintubation Stridor | 1: 0/39 2: 1/38 1: 7/39 2: 10/38 | 0.32 (0.01, 7.73) 0.70 (0.31, 1.59) | 0.49 0.39
Chaney (1998) int 1: Steroids int 2: No Steroids | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Chaney (1998) int 1: Steroids int 2: No Steroids | Duration of Mechanical Ventilation (h) | 1: 12.82 ± 4.90 2: 10.07 ± 5.25 | 2.75 (0.18, 5.32) | 0.04
Chaney (1998) int 1: Steroids int 2: No Steroids | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Chaney (1998) int 1: Steroids int 2: No Steroids | Nonextubation | 1: 0/30 2: 2/30 | 0.20 (0.01, 4.00) | 0.29
Studies of Enteral Nutrition
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
al-Saady (1989) int 1: High Fat Low Carbohydrate Feed int 2: Isocaloric Feed | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
al-Saady (1989) int 1: High Fat Low Carbohydrate Feed int 2: Isocaloric Feed | Change ^2^ in Respiratory Rate Change in Tidal Volume Change in PaCO_2_ Change in PaO_2_ Duration of Mechanical Ventilation From Time That Feed Starts (h) | 1: 0.10 ± 0.60 2: 0.20 ± 2.40 1: 40.20 ± 50.50 2: 46.10 ± 75.60 1: 1.00 ± 0.70 2: 0.20 ±0.80 1: 0.60 ± 2.10 2: 0.50 ±3.80 1: 86.10 ± 17.80 2: 148.70 ± 36.70 | -0.10 (-1.71, 1.51) -5.90 (-63.73, 51.93) 0.80 (0.13, 1.47) 0.10 (-2.68, 2.88) -62.60 ( -88.87, -36.33) | 0.90 0.84 0.02 0.94 <0.01
Vandenberg (1994) int 1: High Fat Low Carbohydrate Feed int 2: Isocaloric Feed | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Vandenberg (1994) int 1: High Fat Low Carbohydrate Feed int 2: Isocaloric Feed | Respiratory Quotient Minute Ventilation During Weaning | 1: 0.72 ± 0.02 2: 0.86 ± 0.02 1: 8.80 ± 0.90 2: 10.50 ± 0.80 | -0.14 (-0.16, -0.12) -1.70 (-2.35, -1.05) | <0.01 <0.01
Vandenberg (1994) int 1: High Fat Low Carbohydrate Feed int 2: Isocaloric Feed | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Vandenberg (1994) int 1: High Fat Low Carbohydrate Feed int 2: Isocaloric Feed | Spontaneous Breathing for 3 h on CPAP | 1: 12/14 2: 13/16 | 1.05 ( 0.78, 1.43) | 0.74
Miscellaneous Studies
Author (Year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Niehoff (1988) int 1: Pulse Oximetry and Capnography int 2: Periodic ABG | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Niehoff (1988) int 1: Pulse Oximetry and Capnography int 2: Periodic ABG | No. Of ABGs Performed Duration of Mechanical Ventilation (h) | 1: 5.90 ± 2.70 2: 10.50 ± 1.80 2: 18.80 ± 2.04 1: 19.70 ± 1.90 | -4.60 (-6.49, -2.71) -0.90 (-2.52, 0.72) | <0.01 0.27
Niehoff (1988) int 1: Pulse Oximetry and Capnography int 2: Periodic ABG | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Niehoff (1988) int 1: Pulse Oximetry and Capnography int 2: Periodic ABG | Nonextubation Reintubation Combined Endpoints: Nonextubation + Reintubation | 1: 0/12 2: 1/12 1: 0/12 2: 0/11 1: 0/12 2: 1/12 | 0.33 (0.01, 7.42) 1.00 0.33 (0.01, 7.42) | 0.49 1.00 0.49
Holliday (1990) int 1: Relaxation Biofeedback int 2: No Relaxation Biofeedback | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Holliday (1990) int 1: Relaxation Biofeedback int 2: No Relaxation Biofeedback | Change in MIP Change in Tidal Volume Change in Minute Ventilation (L/min) Duration of Mechanical Ventilation (d) | 1: 12 ± xx ^1^ 2: 6 ± xx 1: 120 ± xx 2: 51 ± xx 1: 4.41 ± xx 2: 2.67 ± xx 1: 20.6 ± 8.9 2: 32.6 ± 17.6 | -12.0 (-20.6, -3.4) | 0.01
Holliday (1990) int 1: Relaxation Biofeedback int 2: No Relaxation Biofeedback | Binary Variables | Proportion with Event | Relative Risk (98% CI) | P Value
Holliday (1990) int 1: Relaxation Biofeedback int 2: No Relaxation Biofeedback | Nonextubation | 2/20 3/16 | 0.58 (0.13, 2.57) | 0.47
Gust (1996) int 1: Nasal BiPAP (30 min) int 2: CPAP (30 min) int 3: Routine Chest Physiotherapy (10 min) + O_2_ by nasal cannula | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Gust (1996) int 1: Nasal BiPAP (30 min) int 2: CPAP (30 min) int 3: Routine Chest Physiotherapy (10 min) + O_2_ by nasal cannula | Change in Pulmonary Blood Volume Index From End of T-piece Trial to 90 min | 1: 17 ± xx ^1^ 2: 9 ± xx 3: 17 ± xx | 1 vs. 3: 0 2 vs. 3: -8 1 vs. 2: 8
Gust (1996) int 1: Nasal BiPAP (30 min) int 2: CPAP (30 min) int 3: Routine Chest Physiotherapy (10 min) + O_2_ by nasal cannula | Extravascular Lung Water From End of T-piece Trial to 90 min | 1: 0.1 ± xx 2: 0.4 ± xx 3: -0.6 ± xx | 1 vs. 3: 0.7 2 vs. 3: 1.0 1 vs. 2: -0.3
Gust (1996) int 1: Nasal BiPAP (30 min) int 2: CPAP (30 min) int 3: Routine Chest Physiotherapy (10 min) + O_2_ by nasal cannula | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Gust (1996) int 1: Nasal BiPAP (30 min) int 2: CPAP (30 min) int 3: Routine Chest Physiotherapy (10 min) + O_2_ by nasal cannula | Reintubation | 1: 0/25 2: 0/25 3: 0/25 | 1 vs 3: 1.00 2 vs 3: 1.00 1 vs 2: 1.00 | 1.00 1.00 1.00
Pichard (1996) int 1: Recombinant Growth Hormone int 2: No Recombinant Growth Hormone | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Pichard (1996) int 1: Recombinant Growth Hormone int 2: No Recombinant Growth Hormone | Cumulative Duration of Mechanical Support (h) During Weaning | 1: 235.60 ± 55.66 2: 245.40 ± 46.49 | -9.80 (-54.75, 35.15) | 0.67
Pichard (1996) int 1: Recombinant Growth Hormone int 2: No Recombinant Growth Hormone | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Pichard (1996) int 1: Recombinant Growth Hormone int 2: No Recombinant Growth Hormone | Nonextubation at Day 12 | 1: 7/10 2: 7/10 | 1.00 (0.58, 1.72) | 1.00
Lee (1998) | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Jiang (1999) int 1: Nasal BiPAP 30 Minutes int 2: Oxygen by Nasal Prongs and Chest Physiotherapy | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Jiang (1999) int 1: Nasal BiPAP 30 Minutes int 2: Oxygen by Nasal Prongs and Chest Physiotherapy | Reintubation | 1: 13/47 2: 7/46 | 1.76 (0.80, 3.91) | 0.16
int 1: Accupuncture int 2: Control | Laryngospasm | 1: 2/38 2: 9/38 | 0.26 (0.07, 0.98) | 0.05

Evidence Table 8. Pooled results of randomized trials

Studies Comparing Alternative Ventilation Modes for Trials of Unassisted Breathing
CPAP vs. T-Piece
Outcome | Author (Year) | Relative Risk (95% CI) | Summary RR (95% CI) | Heterogeneity X^2^(P Value)
Nonextubation Rate | Feeley (1975) | 1.94 (0.50, 7.47) | 1.66 (0.60, 4.64) | 0.12 (P=0.79)
Nonextubation Rate | Jones (1991) | 1.35 (0.28, 6.54) | 1.66 (0.60, 4.64) | 0.12 (P=0.79)
Reintubation Rate | Feeley (1975) | 4.00 (0.18, 87.19) | 1.71 (0.42, 6.97) | 0.37 (P=0.54)
Reintubation Rate | Jones (1991) | 1.37 (0.28, 6.64) | 1.71 (0.42, 6.97) | 0.37 (P=0.54)
Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support-Noninvasive Ventilation vs. Pressure Support
(1) Binary Variables
Outcome | Author (Year) | Difference (95% CI) | Summary Difference (95% CI) | Heterogeneity X^2^ (P Value)
Mortality | Nava (1998) | 0.33 (0.09, 1.25) | 0.30 (0.09, 1.02) | 0.19 (P=0.73)
Mortality | Girault (1999) | 0.19 (0.01, 3.66) | 0.30 (0.09, 1.02) | 0.19 (P=0.73)
Nosocomial Pneumonia | Nava (1998) | 0.07 (0.00, 1.11) | 0.29 (0.02, 3.88) | 2.15 (P=0.14)
Nosocomial Pneumonia | Girault (1999) | 0.94 (0.11, 8.22) | 0.29 (0.02, 3.88) | 2.15 (P=0.14)
(2) Continuous Variables
ICU Length of Stay | Nava (1998) | -8.90 (-14.67, 3.13) | -5.14 (-12.17, 1.90) | 3.46 (P=0.06)
ICU Length of Stay | Girault (1999) | -1.71 (-6.61, 3.19) | -5.14 (-12.17, 1.90) | 3.46 (P=0.06)
Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support-Duration of Weaning
(1) Pressure Support vs. Multiple Daily T-Piece
Outcome | Author (Year) | Difference (95% CI) | Summary Difference (95% CI) | Heterogeneity X^2^ (P Value)
Duration of Weaning | Brochard (1994) | -67.20 (-143.29, 8.89) | -19.50 (-108.78, 69.79) | 3.16 (P=0.08)
Duration of Weaning | Esteban (1995) | 24.00 (-41.69, 86.69) | -19.50 (-108.78, 69.79) | 3.16 (P=0.08)
(2) SIMV vs. Multiple Daily T-Piece
Duration of Weaning | Brochard (1994) | 33.60 (-54.69, 121.89) | 43.91 (-3.17, 90.98) | 0.07 (P=0.79)
Duration of Weaning | Esteban (1995) | 48.00 (-7.65, 103.65) | 43.91 (-3.17, 90.98) | 0.07 (P=0.79)
(3) PS vs. SIMV
Duration of Weaning | Brochard (1994) | -100.80 (-175.09, -26.51) | -63.98 (-139.18, 11.22) | 1.89 (P=0.17)
Duration of Weaning | Esteban (1995) | -24.00 (-104.31, 56.31) | -63.98 (-139.18, 11.22) | 1.89 (P=0.17)
Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support-Extubation Outcomes
a) Pressure Support vs. Multiple Daily T-Piece
Outcome | Author (Year) | Relative Risk (95% CI) | Summary RR (95% CI) | Heterogeneity X^2^ (P Value)
Combined: Nonextubation and Reintubation | Brochard (1994) | 0.54 (0.26, 1.13) | 0.91 (0.32, 2.58) | 3.52 (P=0.06)
Combined: Nonextubation and Reintubation | Esteban (1995) | 1.58 (0.68, 3.68) | 0.91 (0.32, 2.58) | 3.52 (P=0.06)
b) SIMV vs. Multiple Daily T-Piece
Combined: Nonextubation and Reintubation | Brochard (1994) | 0.98 (0.59, 1.63) | 1.13 (0.71, 1.78) | 1.06 (P=0.30)
Combined: Nonextubation and Reintubation | Esteban (1995) | 1.66 (0.69, 3.95) | 1.13 (0.71, 1.78) | 1.06 (P=0.30)
c) PS vs. SIMV
Combined: Nonextubation and Reintubation | Brochard (1994) | 0.56 (0.27, 1.14) | 0.73 (0.43, 1.24) | 1.09 (P=0.30)
Combined: Nonextubation and Reintubation | Esteban (1995) | 0.96 (0.47, 1.95) | 0.73 (0.43, 1.24) | 1.09 (P=0.30)
Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (Anesthesia Intervention)
(1) Binary Variables
Outcome | Author (Year) | Relative Risk (95% CI) | Summary RR (95% CI) | Heterogeneity X^2^ (P Value)
Mortality | Michalopoulos (1998) | 1.00 (0.02, 49.73) | 0.53 (0.12, 2.35) | 2.67 (P=0.61)
Mortality | Silbert (1998) | 3.31 (0.14, 78.84) | 0.53 (0.12, 2.35) | 2.67 (P=0.61)
Mortality | Berry (1998) | 0.20 (0.01, 3.95) | 0.53 (0.12, 2.35) | 2.67 (P=0.61)
Mortality | Cheng (1996a) | 0.14 (0.01, 2.71) | 0.53 (0.12, 2.35) | 2.67 (P=0.61)
Mortality | Engoren (1998) | 1.00 (0.02, 49.04) | 0.53 (0.12, 2.35) | 2.67 (P=0.61)
Myocardial Infarction | Cheng (1996a) | 0.11 (0.01, 2.02) | 0.59 (0.18, 1.94) | 1.90 (P=0.75)
Myocardial Infarction | Silbert (1998) | 1.10 (0.02, 54.25) | 0.59 (0.18, 1.94) | 1.90 (P=0.75)
Myocardial Infarction | Berry (1998) | 0.98 (0.18, 5.36) | 0.59 (0.18, 1.94) | 1.90 (P=0.75)
Myocardial Infarction | Michalopoulos (1998) | 1.00 (0.02, 49.73) | 0.59 (0.18, 1.94) | 1.90 (P=0.75)
Myocardial Infarction | Engoren (1998) | 0.33 (0.01, 7.91) | 0.59 (0.18, 1.94) | 1.90 (P=0.75)
Arrhythmias | Berry (1998) | 0.98 (0.02, 48.15) | 0.90 (0.39, 2.09) | 0.01 (P = 0.97)
Arrhythmias | Michalopoulos (1998) | 0.89 (0.38, 2.13) | 0.90 (0.39, 2.09) | 0.01 (P = 0.97)
Reintubation | Cheng (1996a) | 3.00 (0.13, 72.21) | 1.48 (0.24, 9.26) | 0.29 (P=0.96)
Reintubation | Michalopoulos (1998) | 1.00 (0.02, 49.73) | 1.48 (0.24, 9.26) | 0.29 (P=0.96)
Reintubation | Silbert (1998) | 0.91 (0.02, 44.63) | 1.48 (0.24, 9.26) | 0.29 (P=0.96)
Reintubation | Engoren (1998) | 1.00 (0.02, 49.04) | 1.48 (0.24, 9.26) | 0.29 (P=0.96)
Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (Anesthesia Intervention)
(2) Continuous Variables
Outcome | Author (Year) | Difference (95% CI) | Summary Difference (95% CI) | Heterogeneity X^2^ (P Value)
ICU Length of Stay | Cheng (1996a) | -1.70 (-6.46, 3.06) | -3.59 (-7.49, 0.30) | 13.37 (P<0.01)
ICU Length of Stay | Berry (1998) | 0.00 (-10.76, 10.76) | -3.59 (-7.49, 0.30) | 13.37 (P<0.01)
ICU Length of Stay | Michalopoulos (1998) | -6.96 (-7.37, -6.55) | -3.59 (-7.49, 0.30) | 13.37 (P<0.01)
ICU Length of Stay | Engoren (1998) | -2.00 (-5.58, 1.58) | -3.59 (-7.49, 0.30) | 13.37 (P<0.01)
Hospital Length of Stay | Cheng (1996a) | -1.20 (-2.38, -0.02) | -1.06 (-1.32, -0.80) | 2.42 (P=0.66)
Hospital Length of Stay | Silbert (1998) | 1.00 (-5.90, 7.90) | -1.06 (-1.32, -0.80) | 2.42 (P=0.66)
Hospital Length of Stay | Berry (1998) | 0.00 (-1.52, 1.52) | -1.06 (-1.32, -0.80) | 2.42 (P=0.66)
Hospital Length of Stay | Michalopoulos (1998) | -1.10 (-1.38, -0.82) | -1.06 (-1.32, -0.80) | 2.42 (P=0.66)
Hospital Length of Stay | Engoren (1998) | -0.90 (-2.06, 0.26) | -1.06 (-1.32, -0.80) | 2.42 (P=0.66)
Duration of Mechanical Ventilation | Cheng (1996a) | -14.80 (-15.29, -14.31) | -6.86 (-13.26, -0.47) | 1253.49 (P<0.01)
Duration of Mechanical Ventilation | Silbert (1998) | -3.00 (-8.27, 2.27) | -6.86 (-13.26, -0.47) | 1253.49 (P<0.01)
Duration of Mechanical Ventilation | Berry (1998) | -10.79 (-13.73, -7.85) | -6.86 (-13.26, -0.47) | 1253.49 (P<0.01)
Duration of Mechanical Ventilation | Michalopoulos (1998) | -4.30 (-4.64, -3.96) | -6.86 (-13.26, -0.47) | 1253.49 (P<0.01)
Duration of Mechanical Ventilation | Engoren (1998) | -1.02 (-2.08, 0.77) | -6.86 (-13.26, -0.47) | 1253.49 (P<0.01)
Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (ICU Interventions)
(1) Binary Variables
Outcome | Author (Year) | Relative Risk (95% CI) | Summary RR (95% CI) | Heterogeneity X^2^ (P Value)
ICU Mortality | Shackford (1981) | 1.06 (0.02, 50.44) | 1.20 (0.63, 2.27) | 0.00 (P=1.00)
ICU Mortality | Reyes (1997) | 1.21 (0.63, 2.30) | 1.20 (0.63, 2.27) | 0.00 (P=1.00)
Reintubation | Quasha (1980) | 3.32 (0.14, 76.60) | 2.69 (1.06, 6.87) | 0.54 (P=0.91)
Reintubation | Shackford (1981) | 1.06 (0.02, 50.44) | 2.69 (1.06, 6.87) | 0.54 (P=0.91)
Reintubation | Tempe (1995) | 1.00 (0.02, 49.44) | 2.69 (1.06, 6.87) | 0.54 (P=0.91)
Arrhythmias | Quasha (1980) | 0.77 (0.27, 2.14) | 0.60 (0.36, 1.02) | 0.38 (P=0.83)
Arrhythmias | Shackford (1981) | 1.06 (0.02, 50.44) | 0.60 (0.36, 1.02) | 0.38 (P=0.83)
Arrhythmias | Reyes (1997) | 0.55 (0.29, 1.02) | 0.60 (0.36, 1.02) | 0.38 (P=0.83)
(2) Continuous Variables
ICU Length of Stay | Quasha (1980) | -0.46 (-1.03, 0.11) | -0.55 (-0.90, -0.19) | 0.14 (P=0.71)
ICU Length of Stay | Shackford (1981) | -0.60 (-1.05, -0.15) | -0.55 (-0.90, -0.19) | 0.14 (P=0.71)
Duration of Mechanical Ventilation | Quasha (1980) | -16.00 (-17.58, -14.42) | -12.59 (-18.71, -6.47) | 115.99 (P<0.01)
Duration of Mechanical Ventilation | Shackford (1981) | -15.00 (-16.39, -13.61) | -12.59 (-18.71, -6.47) | 115.99 (P<0.01)
Duration of Mechanical Ventilation | Dumas (1999) | -6.83 (-7.96, -5.70) | -12.59 (-18.71, -6.47) | 115.99 (P<0.01)
Pediatric Studies of Corticosteroids to Prevent Postextubation Airway Complications
Outcome | Author Year) | Relative Risk (95% CI) | Summary RR (95% CI) | Heterogeneity X^2^ (P Value)
Reintubation | Tellez (1991) | 2.14 (0.73, 6.28) | 0.68 (0.16, 2.97) | 6.26 (P=0.04)
Reintubation | Anene (1996) | 0.07 (0.00, 1.15) | 0.68 (0.16, 2.97) | 6.26 (P=0.04)
Reintubation | Harel (1997) | 0.59 (0.20, 1.74) | 0.68 (0.16, 2.97) | 6.26 (P=0.04)
Stridor | Tellez (1991) | 0.71 (0.41, 1.23) | 0.58 (0.42, 0.81) | 0.77 (P=0.38)
Stridor | Anene (1996) | 0.52 (0.35, 0.79) | 0.58 (0.42, 0.81) | 0.77 (P=0.38)
Adult Studies of Corticosteroids to Prevent Postextubation Airway Complications
Reintubation | Gaussorgues (1987) | 9.00 (0.49, 165.60) | 0.93 (0.15, 5.81) | 3.45 (P=0.18)
Reintubation | Darmon (1992) | 0.47 (0.11, 2.07) | 0.93 (0.15, 5.81) | 3.45 (P=0.18)
Reintubation | Ho (1996) | 0.33 (0.01, 7.74) | 0.93 (0.15, 5.81) | 3.45 (P=0.18)
Lanyngeal Lesions | Gaussorgues (1987) | 1.80 (0.39, 8.30) | 0.87 (0.38, 2.00) | 1.28 (P=0.26)
Lanyngeal Lesions | Darmon (1992) | 0.68 (0.33, 1.40) | 0.87 (0.38, 2.00) | 1.28 (P=0.26)

Evidence Table 9. Methodologic characteristics of nonrandomized controlled clinical trials, grouped according to intervention type

Nonrandomized Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support
Author (year) | ICU Population | Diagnoses | Baseline Similarity | Cointervention Similarity | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Patel (1999) | Adult ICU patients (n=42) | COPD, pneumonia, neurological, airway protection | Yes for: age, prestudy time on ventilation, P/F ratio, proportion with pneumonia, COPD, NMD | Not demonstrated | Yes | No | No
Hilbert (1998a) | Adult MICU (n=60) | Postextubation hypercapnia respiratory failure, COPD | Yes for: age, prestudy time on ventilation, proportion with VAP, SAPS, P/F ratio | Yes for proportion ever received, systemic steroids, diuretics, antibiotics | N/A | N/A | No
Nonrandomized Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support Lasting Less Than 48 Hours
Tomlinson (1989) | Patients in a tertiary care medical-surgical ICU (n=165) | COPD, CHF, post-op, neurological, cardiac bypass surgery, cardiac valve surgery, trauma | Yes for: age, proportion post-op | Not demonstrated | Yes | No | No
Rathgeber (1997) | Adult postcardiac surgery (n=596) | Cardiac bypass surgery | Yes for: age, proportion post-op, prestudy time on ventilation, proportion with pneumonia, VAP, COPD, NMD, ARDS | No: more sedatives in T-piece group | Yes | Yes | No
Nonrandomized Studies Comparing Weaning Protocols to Physician-directed Weaning
Author (year) | ICU Population | Diagnoses | Baseline Similarity | Cointervention Similarity | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Foster (1984) | Adult postcardiac surgery (n=63) | Cardiac bypass surgery | Yes for: age, proportion post-op | Not demonstrated | Yes | Yes | No
Tong (1991) | (n=54) | Postoperative | Yes for: age, proportion post-op | Not demonstrated | No | No | No
Rotello (1992) | Adult general (n=63) | COPD, pneumonia, post-op, trauma | Yes for: proportion with pneumonia, COPD | Not demonstrated | Yes | No | No
Wood (1995) | Adult postcardiac surgery (n=284) | Cardiac bypass surgery, cardiac valve surgery | Yes for: age, proportion post-op | Not demonstrated | Yes | Yes | No
Saura (1996a) | Adult general (n=101) | COPD, neurological | Yes for: age, pre-study time on ventilation, COPD, APACHE II | Not demonstrated | Yes | Yes | No
Results-Nonrandomized Studies Comparing Weaning Protocols with Physician-directed Weaning
Author (year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Djunaedi (1997) | Adult MICU (n=107) | Post-op, trauma | Yes for: age, proportion post-op, APACHE II | Not demonstrated | Yes | Yes | No
Burns (1998) | Adult MICU (n=409) | COPD, asthma, pneumonia, lung injury, post-op, neuromuscular, neurological, airway protection, trauma | Yes for: proportion post-op, prestudy time on ventilation, proportion with NMD | Not demonstrated | Yes | No | No
Horst (1998) | Adult general (n=893) | Postoperative | Yes for: proportion post-op, APACHE II | Not demonstrated | Yes | Yes | No
Kollef (1998a) | Adult and some not reported (n=347) | Surgical | Not demonstrated | Not demonstrated | No | No | No
Kollef (1998b) | Adult general (n=88) | Not reported | Yes for: age, MPM | Not demonstrated | No | No | No
Kollef (1998c) | Adult general (n is not reported) | Not reported | Yes for: age | Not demonstrated | No | No | No
Nonrandomized Studies Comparing Early vs Late Extubation Following Cardiac Surgery (Anesthesia Intervention)
London (1997) | CVICU VA hospitals (n=559) | Cardiac surgery | Yes for: age, proportion post-op, proportion with COPD | Not demonstrated | No | No | No
Nonrandomized Studies Comparing Early vs Late Extubation Following Cardiac Surgery (ICU)
Chong (1993) | Adult cardiac surgery (n=278) | Cardiac bypass surgery, cardiac valve surgery, congenital heart disease | Yes for: age, proportion post-op | Not demonstrated | Yes | Yes | No
Engelman (1994) | Adult postcardiac surgery (n=562) | Cardiac bypass surgery | Yes for: age, proportion post-op | Not demonstrated | No | No | No
Lee (1996) | Adult cardiac surgery (n=690) | Cardiac bypass surgery | Yes for: age, proportion post-op | Not demonstrated | No | Yes | No
Johnson (1997) | Adult cardiac surgery (n=143) | Cardiac bypass surgery | Yes for: age, proportion post-op (matched controls) | Yes for: proportion ever received sedatives, bronchodilators | No | No | No
Quigley (1997) | Adult cardiac surgery (n=532) | Cardiac bypass surgery | Yes for: age, proportion post-op | Not demonstrated | No | No | No
Sugahara (1999) | Adult CVICU (n=34) | Post-op, cardiac bypass surgery, cardiac valve surgery | Yes for: age, proportion post-op, prestudy time on ventilation, receiving sedatives, receiving NM blockers | Yes for: proportion ever received sedatives No for: proportion ever received inotropes | No | No | No
Nonrandomized Studies Comparing Early vs Late Extubation Following Cardiac Surgery (Pediatrics)
Laussen (1996) | Pediatric cardiac surgery (n=102) | ASD repair | Yes for: age, proportion post-op | Not demonstrated | No | No | No
Nonrandomized Studies of Corticosteroids to Prevent Post-Extubation Airway (Pediatrics)
Author (year) | ICU Population | Diagnoses | Baseline Similarity | Cointervention Similarity | Weaning Criteria Reported | Extubation Criteria Reported | Reintubation Criteria Reported
Freezer (1990) | Pediatric ICU (n=59) | Croup failed first extubation | Yes for: age, prestudy time on ventilation No for: history of croup | No for: proportion ever received systemic steroids | No | No | No
Nonrandomized Studies of Enteral Nutrition
Bassili (1981) | Adult medical and surgical ICU patients (n=47) | COPD, Pneumonia, post-op, trauma | Yes for: proportion post-op, pre-study time on ventilation, proportion with COPD | Yes for: proportion ever received enteric feeding | No | No | No

Evidence Table 10. Results of individual nonrandomized controlled clinical trials

Results-Nonrandomized Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support
Author (year) Study Interventions | Outcome | Results | Magnitude of Effect | P Value
Patel (1999) int 1: 24 h 5 PS + 5 PEEP 24 h Intermittent Nasal CPAP int 2: 24 h 5 PS + 5 PEEP 24 h Invasive CPAP | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Patel (1999) int 1: 24 h 5 PS + 5 PEEP 24 h Intermittent Nasal CPAP int 2: 24 h 5 PS + 5 PEEP 24 h Invasive CPAP | Reintubation within 48 h of extubation | 1: 2/20 2: 4/20 | 0.61 (0.15, 2.56) | 0.50
Hilbert (1998a) int 1: Intermittent noninvasive ventilation int 2: Conventional management | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Hilbert (1998a) int 1: Intermittent noninvasive ventilation int 2: Conventional management | Hospital mortality Reintubation | 1: 2/30 2: 6/30 1: 6/30 2: 20/30 | 0.38 (0.10, 1.51) 0.15 (0.15, 0.66) | 0.17 <0.01
Results-Nonrandomized Studies Comparing Alternative Ventilation Modes for Stepwise Reductions in Mechanical Support Lasting Less than 48 Hours
Tomlinson (1989) int 1: IMV (± PEEP) int 2: Multiple Daily T-Piece | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Tomlinson (1989) int 1: IMV (± PEEP) int 2: Multiple Daily T-Piece | Duration of Mechanical Ventilation (h) Duration of Weaning (h) | 1: 115.50 ± 479.14 2: 67.40 ± 99.99 1: 5.30 ± 11.88 2: 5.90 ± 14.14 | 48.10 (-46.96, 143.16) -0.60 (-4.23, 3.03) | 0.32 0.75
h = hours; d = days
Rathgeber (1997) int 1: Invasive BiPAP int 2: SIMV with Pressure Support + CPAP int 3: Intermittent T-Piece | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Rathgeber (1997) int 1: Invasive BiPAP int 2: SIMV with Pressure Support + CPAP int 3: Intermittent T-Piece | Duration of Intubation (h) | 1: 10.10 ± 3.30 2: 14.70 ± 4.00 3: 13.20 ± 4.20 | 1 vs. 3:-3.10 (-4.50,-1.70) 2 vs. 3: 1.50 (0.69, 2.31) 1 vs. 2: -4.60 (-5.85,-3.35) | <0.01 <0.01 <0.01
Rathgeber (1997) int 1: Invasive BiPAP int 2: SIMV with Pressure Support + CPAP int 3: Intermittent T-Piece | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Rathgeber (1997) int 1: Invasive BiPAP int 2: SIMV with Pressure Support + CPAP int 3: Intermittent T-Piece | Reintubation | 1: 0/658 2: 0/709 3: 1/721 | 1 vs. 3: 0.37 (0.01, 8.95) 2 vs. 3: 0.34 (0.01, 8.31) 1 vs. 2: 1.08 (0.02,54.23) | 0.54 0.51 0.97
Nonrandomized Studies Comparing Weaning Protocols with Physician-directed Weaning
Foster (1984) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Foster (1984) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Duration of Mechanical Ventilation (h) Duration of Intubation (h) Number of ABGs performed | 1: 10.80 ± 4.50 2: 18.20 ± 8.50 1: 9.80 ± 4.40 2: 16.50 ± 8.00 1: 6.60 ± 2.00 2: 11.40 ± 5.30 | -7.40 (-10.65, -4.15) -6.70 (-9.79, -3.61) -4.80 (-6.68, -2.92) | <0.01 <0.01 <0.01
Foster (1984) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
| Nonextubation | 1: 22/36 2: 26/27 | 0.64 (0.49, 0.83) | <0.01
Tong (1991) int 1: Computer-directed int 2: Physician-directed | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Tong (1991) int 1: Computer-directed int 2: Physician-directed | No of ABGs Performed | 1: 3.40 ± 0.50 2: 6.20 ± 1.90 | -2.80 (-3.85, -1.75) | <0.01
Rotello (1992) int 1: Nurse-directed Oxygen Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Rotello (1992) int 1: Nurse-directed Oxygen Weaning Protocol int 2: Physician-directed Wean | Duration of Weaning (m) Number of ABGs Performed | 1: 170.00 ± 93.00 2: 307.00 ± 131.00 3: 1.06 ± 0.24 4: 2.85 ± 0.69 | -137.00 (-199.00,-75.00) -1.79 (-2.02, -1.56) | <0.01 <0.01
Wood (1995) int 1: Respiratory Therapist-directed IMV Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Wood (1995) int 1: Respiratory Therapist-directed IMV Weaning Protocol int 2: Physician-directed Wean | Duration of Mechanical Ventilation (h) Duration of Weaning (h) | 1: 19.78 ± 7.58 2: 21.00 ± 9.60 1: 3.01 ± 2.93 2: 3.30 ± 4.65 | -1.22 (-3.62, 1.18) -0.29 (-1.42, 0.84) | 0.32 0.61
Wood (1995) int 1: Respiratory Therapist-directed IMV Weaning Protocol int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Wood (1995) int 1: Respiratory Therapist-directed IMV Weaning Protocol int 2: Physician-directed Wean | Reintubation | 1: 1/55 2: 3/142 | 1.10 (0.17, 7.27) | 0.92
Saura (1996) int 1: Protocol-directed Wean int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Saura (1996) int 1: Protocol-directed Wean int 2: Physician-directed Wean | ICU Length of Stay (d) Duration of Mechanical Ventilation (d) Duration of Weaning (d) | 1: 16.70 ± 16.50 2: 20.30 ± 13.20 1: 10.40 ± 11.60 2: 14.40 ± 10.30 1: 3.50 ± 3.90 2: 3.60 ± 2.20 | -3.60 (-9.43, 2.23) -4.00 (-8.28, 0.28) -0.10 (-1.34, 1.14) | 0.23 0.07 0.87
Saura (1996) int 1: Protocol-directed Wean int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Saura (1996) int 1: Protocol-directed Wean int 2: Physician-directed Wean | ICU Mortality Nonextubation Reintubation Tracheostomy | 1: 4/51 2: 8/50 1: 5/51 2: 4/50 1: 9/51 2: 7/50 1: 1/51 2: 4/50 | 0.52 (0.18, 1.52) 1.20 (0.37, 3.92) 1.24 (0.52, 2.98) 0.33 (0.05, 1.99) | 0.23 0.76 0.63 0.23
Djunaedi (1997) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Djunaedi (1997) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Duration of Mechanical Ventilation (d) | 1: 3.89 ± 4.43 2: 3.18 ± 3.98 | 0.71 (-0.89, 2.31) | 0.39
Burns (1998) int 1: Multidisciplinary Protocol-directed Wean int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Burns (1998) int 1: Multidisciplinary Protocol-directed Wean int 2: Physician-directed Wean | Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 12.70 ± 15.14 2: 14.80 ± 15.68 1: 11.60 ± 12.47 2: 12.90 ± 13.57 | -2.10 (-6.73, 2.53) -1.30 (-5.23, 2.63) | 0.37 0.52
Horst (1998) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Horst (1998) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Duration of Mechanical Ventilation (h) | 1: 112.60 ± 164.00 2: 170.60 ± 164.00 | -58.00 (-79.77, -36.23) | <0.01
Horst (1998) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Horst (1998) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | ICU Mortality Reintubation | 1: 63/515 2: 55/378 1: 2/515 2: 6/378 | 0.84 (0.60, 1.17) 0.28 (0.07, 1.21) | 0.31 0.09
Kollef (1998) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Kollef (1998) int 1: Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | ICU Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 4.40 ± xx ^1^ 2: 6.07 ± xx 1: 121.90 ± xx 2: 170.60 ± xx | -1.67 -48.70
Kollef (1998) int 1: Nurse + Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Kollef (1998) int 1: Nurse + Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Hospital Length of Stay (d) ICU Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 8.00 ± xx ^1^ 2: 11.00 ± xx 1: 4.00 ± xx 2: 8.00 ± xx 1: 72.00 ± xx 2: 144.00 ± xx | -3.00 -4.00 -72.00
Kollef (1998) int 1: Nurse + Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Kollef (1998) int 1: Nurse + Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Hospital Mortality | 1: 14/53 2: 11/35 | 0.84 (0.44, 1.60) | 0.59
Kollef (1998) int 1: Nurse + Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Kollef (1998) int 1: Nurse + Respiratory Therapist-directed Weaning Protocol int 2: Physician-directed Wean | Hospital Length of Stay (d) ICU Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 15.60 ± xx ^1^ 2: 20.20 ± xx 1: 5.80 ± xx 2: 8.10 ± xx 1: 21.60 ± xx 2: 112.80 ± xx | -4.60 -2.30 -43.20
Results-Nonrandomized Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (Anesthesia Intervention)
London (1997) int 1: Early int 2: Late | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
London (1997) int 1: Early int 2: Late | ICU Length of Stay (h) Hospital Length of Stay (h) Duration of Mechanical Ventilation (h) | 1: 91.0 ± 145.0 2: 144.0 ± 204.0 1: 228.0 ± 252.0 2: 291.0 ± 213.0 1: 17.3 ± 28.6 2: 27.8 ± 28.3 | -53.0 (-82.03, -23.97) -63.0 (-102.12, -23.88) -10.5 (-15.24, -5.76) | <0.01 <0.01 <0.01
London (1997) int 1: Early int 2: Late | Binary Variables | Proportion with Event | Relative Risk (95% CI)
| 30-day Mortality Reintubation Arrhythmias Nosocomial Pneumonia | 1: 14/304 2: 10/255 1: 15/304 2: 16/255 1: 78/304 2: 56/255 1: 22/304 2: 37/255 | 1.16 (0.53, 2.52) 0.79 (0.40, 1.55) 1.17 (0.86, 1.57) 0.50 (0.31, 0.83) | 0.71 0.49 0.31 0.01
Results-Nonrandomized Studies Comparing Early vs. Late Extubation Following Cardiac Surgery (ICU Intervention)
Chong (1993) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95%CI)
Chong (1993) int 1: Early Extubation int 2: Late Extubation | Hospital Length of Stay (d) Duration of Mechanical Ventilation (h) Duration of Intubation (h) | 1: 7.60 ± 3.30 2: 7.90 ± 2.10 1: 1.00 ± xx ^1^ 2: 5.00 ± xx 1: 2.00 ± xx 2: 7.00 ± xx | -0.30 (-1.08, 0.48) -4.00 -5.00 | 0.45 <0.05 <0.05
Chong (1993) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Chong (1993) int 1: Early Extubation int 2: Late Extubation | Hospital Mortality Reintubation | 1: 2/193 2: 0/80 1: 5/193 2: 0/80 | 2.08 (0.10, 42.85) 4.58 (0.26, 81.80) | 0.64 0.30
Engelman (1994) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Engelman (1994) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (d) Duration of Intubation (h) | 1: 1.90 ± 0.10 2: 2.40 ± 0.10 1: 15.40 ± 2.00 2: 22.10 ± 1.10 | -0.50 (-0.52, -0.48) -6.70 (-6.97, -6.43) | <0.01 <0.01
Engelman (1994) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Engelman (1994) int 1: Early Extubation int 2: Late Extubation | Hospital Mortality Myocardial Infarction | 1: 10/280 2: 11/282 1: 6/280 2: 5/282 | 0.92 (0.40, 2.09) 1.19 (0.39, 3.66) | 0.84 0.76
Lee (1996) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95%CI)
Lee (1996) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (d) Hospital Length of Stay (d) | 1: 2.03 ± 2.67 2: 2.36 ± 2.93 1: 9.87 ± 8.58 2: 11.84 ± 10.12 | -0.33 (-0.75, 0.09) -1.97 (-3.37, -0.57) | 0.12 0.01
Lee (1996) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
| Hospital Mortality Myocardial Infarction Arrhythmias Nosocomial Pneumonia | 1: 11/362 2: 12/328 1: 13/362 2: 6/328 1: 82/362 2: 63/328 1: 4/362 2: 1/328 | 0.83 (0.38, 1.83) 1.88 (0.75, 4.74) 1.18 (0.88, 1.58) 2.72 (0.43, 17.15) | 0.65 0.18 0.27 0.29
Johnson (1997) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Johnson (1997) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 1.30 ± 4.00 2: 2.80 ± 3.00 1: 7.00 ± 3.50 2: 22.00 ± 9.20 | -1.50 (-2.79, -0.21) -15.00 (-18.31, -11.39) | 0.02 <0.01
Johnson (1997) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Johnson (1997) int 1: Early Extubation int 2: Late Extubation | Nosocomial Pneumonia | 1: 2/31 2: 6/112 | 1.37 (0.34, 5.59) | 0.66
Quigley (1997) int 1: Early Extubation int 2: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Quigley (1997) int 1: Early Extubation int 2: Late Extubation | ICU Length of Stay (d) Hospital Length of Stay (d) Duration of Intubation (h) | 1: 1.70 ± 0.80 2: 2.60 ± 0.60 1: 6.40 ± 1.20 2: 7.50 ± 0.90 1: 10.16 ± 10.80 2: 38.40 ± 6.38 | -0.90 (-1.02, -0.78) -1.10 (-1.28, -0.92) -28.24 (-29.75, -26.73) | <0.01 <0.01 <0.01
Quigley (1997) int 1: Early Extubation int 2: Late Extubation | Binary Variables | Proportion with Event | Relative Risk (95% CI)
Quigley (1997) int 1: Early Extubation int 2: Late Extubation | ICU Mortality Nonextubation at 24 h ICU Discharge at 24-48 h | 1: 5/266 2: 6/266 1: 13/266 2: 266/266 1: 218/266 2: 128/266 | 0.85 (0.28, 2.60) 0.05 (0.03, 0.09) 1.70 (1.48, 1.95) | 0.77 <0.01 <0.01
Sugahara (1999) int 1: Early int 2: Late | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Sugahara (1999) int 1: Early int 2: Late | ICU Length of Stay (d) Duration of Mechanical Ventilation (h) | 1: 4.90 ± 1.80 2: 5.70 ± 2.10 1: 4.10 ± 2.70 2: 5.30 ± 4.40 | -0.80 (-2.11, 0.51) -1.20 (-3.65, 1.25) | 0.23 0.34
Results-Nonrandomized Studies of Early vs. Late Extubation Following Cardiac Surgery (Pediatrics)
Laussen (1996) int 1: Very Early Extubation (in OR) int 2: Early Extubation int 3: Late Extubation | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
Laussen (1996) int 1: Very Early Extubation (in OR) int 2: Early Extubation int 3: Late Extubation | ICU Length of Stay (h) Hospital Length of Stay (d) Duration of Intubation (h) | 1: 28.30 ± 11.20 2: 27.40 ± 9.60 3: 31.90 ± 18.70 1: 3.40 ± 0.60 2: 3.50 ± 0.70 3: 5.10 ± 0.60 1: N/A 2: 6.80 ± 8.50 3: 8.30 ± 6.00 | 1 vs. 3: -3.60 (-11.80, 4.60) 2 vs. 3: -4.50 (-11.02, 2.02) 1 vs. 2: 0.90 (-4.19, 5.99) 1 vs. 3: -1.70 (-2.01, -1.39) 2 vs. 3: -1.60 (-1.89, 1.31) 1 vs. 2: -0.10 (-0.43, 0.23) 2 vs. 3: -1.50 (-4.83, 1.83) | 0.39 0.18 0.73 <0.01 <0.01 0.55 0.38
Results-Nonrandomized Studies of Corticosteroids to Prevent Postextubation Airway Complications (Pediatrics)
Freezer (1990) int 1: Steroids int 2: No Steroids | Binary Variables | Proportion with | Relative Risk (95% CI)
Freezer (1990) int 1: Steroids int 2: No Steroids | Failed Reextubation | 1: 0/16 2: 26/43 | 0.05 (0.00, 0.77) | 0.03
Results-Nonrandomized Studies of Enteral Nutrition
2705 Bassili (1981) int 1: D5W int 2: TPN or NG Feeds | Continuous Variables | Mean ± Standard Deviation | Difference in Means (95% CI)
2705 Bassili (1981) int 1: D5W int 2: TPN or NG Feeds | Duration of Mechanical Ventilation (d) | 1: 9.2 ± xx ^1^ 2: 9.3 ± xx | -0.1
2705 Bassili (1981) int 1: D5W int 2: TPN or NG Feeds | Binary Variables | Proportion with Event | Relative Risk (95% CI)
2705 Bassili (1981) int 1: D5W int 2: TPN or NG Feeds | Nonextubation | 1: 15/33 2: 1/14 | 4.47 (0.94, 21.26) | 0.06

Evidence Table 11. Characteristics of observational studies

Critical Appraisal Question | Number of Studies
Was there a representative sample of patients?
Yes | 31
Unclear | 8
No - patients selected according to results of extubation trial (pass or fail) | 1
No - artificial case mix (e.g., normal post-op plus pulmonary fibrosis) | 29
Is the person deciding on patient status on the dependent variable the same person who is measuring the prediction variables?
Yes | 10
Unclear | 15
Not reported | 12
No - the person deciding on extubation/reintubation/altering level of support is aware of all prediction variables | 6
No- the person deciding on extubation/reintubation/altering level of support is aware of some prediction variables | 10
No - the person deciding on extubation/reintubation/altering level of support is unaware of predicition variables | 9
No - the person deciding on extubation/reintubation/altering level of support is privy to raw data but not derived data | 1
No - the person deciding on extubation/reintubation/altering level of support is unable to access predictors | 0
No- unclear | 2
No - not reported | 5
Did the authors report practice patterns with respect to each of the following issues within the study ICU?
Tracheostomy (who, what proportion) - Yes | 6
Tracheostomy (who, what proportion) - No | 63
NPPV (who, what proportion) - Yes | 1
NPPV (who, what proportion) - No | 68
Dependent Variable or Outcome (may be more than one choice) | No. of Studies
1. Successful stepwise decrease in level of mechanical support | 5
Pressure support (PS) | 3
Intermittent mandatory ventilation (IMV) | 2
Volume support | 0
Daily time on T-piece | 0
PEEP | 0
Other | 2
2. Successful discontinuation assessment test prior to extubation | 18
T-piece | 9
CPAP | 4
CPAP/PS | 0
Other | 3
3. Successful trial of extubation (when deemed "ready") | 30
Duration of monitoring during which reintubation is identified not reported | 6
Duration of monitoring during which reintubation is identified <6 hours | 0
Duration of monitoring during which reintubation is identified 6.1 to 12 hours | 0
Duration of monitoring during which reintubation is identified 12.1 to 24 hours | 9
Duration of monitoring during which reintubation is identified 24.1 to 48 hours | 7
Duration of monitoring during which reintubation is identified >48 hours | 3
Duration of monitoring during which reintubation is identified as other | 4
Criteria for failure reported - quantitative criteria | 9
Criteria for failure reported - nonquantitative criteria | 7
Criteria for failure not reported | 5
4. Combination of 2 and 3 | 13
5. Combination of 1, 2, and 3 | 2
6. Weaned and successfully extubated any time (outcome evaluated from before the start of the weaning trial until the end of followup) | 6
7. Duration of ventilation in COPD patients | 1
8. Duration of ventilation in cardiac patients | 10
Classification of Predictors | No. of Studies
subjective (e.g., Diaphoresis, anxiety) | 10
vital signs (e.g., HR, RR, BP) | 64
lung mechanics (e.g., VT, PIP, f/VT) | 313
composite scores or derivations (e.g., CROP) | 66
level of nonrespiratory care (e.g., inotropes, sedatives) | 35
diagnostic category | 150
other | 302
Classification of Predictor Data
Actual data type
binary | 214
categorical | 26
continuous (includes plots) | 701
Reported Data Type
binary | 268
categorical | 49
continuous (includes plots) | 624
Format of Results (May Be More than One Choice)
allows only 2X2 table | 532
allows 2Xn table | 40
logistic regression | 70
means | 354

Evidence Table 12. Methodologic characteristics of observational studies, grouped according to outcome

Successful Stepwise Decrease in Mechanical Support
Author (year) | ICU Population | Diagnoses | Representative Sample | Blinding of Outcome Assessor
Oh (1991) | Adult general (n=20) | COPD, CHF, post-op, cardiac bypass surgery, cardiac valve surgery | Yes | Partial
Linton (1994) | Adult general (n=27) | COPD, pneumonia, CHF, lung injury, post-op | Unclear | Likely unblinded
Stroetz (1995) | Adult general (n=31) | COPD, lung injury | Yes | Likely unblinded
Rivera (1997) | Adult general (n=40) | post-op | No: according to case mix | Unblinded
Successful Discontinuation Assessment
Delooz (1976) | Adult postcardiac surgery (n=41) | Cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Likely unblinded
Hilberman (1976) | Adult (n=124) | Post-op, cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Likely unblinded
Kennedy (1977) | Adult (n=20) | Pneumonia, CHF, post-op, cardiac bypass surgery, cardiac valve surgery, trauma | Unclear | Unblinded
Jabour (1991) | Adult general (n=38) | COPD, pneumonia, lung injury, postop, neuromuscular, neurological, airway protection, trauma, | Yes | Likely unblinded
Sassoon (1993) | Adult general (n=45) | COPD, pneumonia, CHF, neurological | Unclear | Fully blinded
Frutos (1995) | Adult general (n=73) | COPD, CHF, post-op, neuromuscular, neurological, trauma | Unclear | Likely unblinded
Chatila (1996b) | Adult general (n=100) | COPD, asthma, pneumonia, CHF, neurological, airway protection | Yes | Unblinded
Dojat (1996) | Adult general (n=38) | COPD, asthma, pneumonia, CHF, hemodynamic instability, post-op | Yes | Likely unblinded
Saura (1996b) | Adult general (n=30) | COPD, trauma | Unclear | Likely unblinded
Chao (1997) | Adult general (n=174) | COPD | Yes | Likely unblinded
Del Rosario (1997) | Adult general (n=49) | COPD, pneumonia, CHF, neurological | Yes | Likely unblinded
Successful Extubation
Author (year) | ICU Population | Diagnoses | Representative Sample | Blinding of Outcome Assessor
Tahvanainen (1983) | Adult (n=47) | CHF, acute lung ingury, neuromuscular | Yes | Likely unblinded
Adderley (1987) | Pediatric (n=28) | Croup | No: according to case mix | Unblinded
Kline (1987) | Adult general (n=50) | COPD, pneumonia, post-op, cardiac bypass surgery, cardiac valve surgery | Yes | Partial
Fisher (1992) | Adult general (n=72) | COPD, asthma, cardiac bypass surgery, trauma | Unclear | Unblinded
Ochiai (1993) | Adult general (n=38) | Post-op | No: according to case mix | Likely unblinded
Yang (1993) | Adult general (n=31) | Pneumonia, CHF, lung injury, neuromuscular, airway protection | Yes | Fully blinded
Lee (1994) | Adult general (n=52) | COPD, pneumonia, CHF, neurological | Unclear | Likely unblinded
Epstein (1995) | Adult general (n=94) | COPD, asthma, pneumonia, CHF, lung injury, hemodaynamic instability, neuromuscular, neurological | Yes | Unblinded
DeHaven (1996) | Adult general (n=589) | Trauma | No: according to case mix | Likely unblinded
Mergoni (1996) | Adult general (n=51) | Hemodynamic instability, post-op, neurological, trauma | Yes | Likely unblinded
el-Khatib (1996) | Pediatric (n=50) | Asthma, pneumonia, lung injury, hemodynamic instability, post-op, neurological, airway protection, cardiac bypass surgery, cardiac valve surgery, infant RDS, trauma | Yes | Fully blinded
Ely (1996) | Adult (n=300) | COPD, asthma, pneumonia, CHF, acute lung injury, neurological | Yes | Unblinded
Epstein (1996) | Adult general (n=218) | COPD, asthma, pneumonia, CHF, hemodynamic instability, neuromuscular, neurological | Yes | Partial
Khan (1996) | Pediatric and some not reported (n=213) | Not reported | Yes | Partial
Leitch (1996) | Adult general (n=163) | COPD | Yes | Unblinded
Baumeister (1997) | Pediatric (n=47) | Asthma, pneumonia, hemodynamic instability, post-op, neurological, airway protection, congenital heart disease, trauma | Yes | Partial
Gologorskii (1997) | Adult surgical (n=127) | Post-op | No: according to case mix | Likely unblinded
Krieger (1997) | Adult general (n=49) | COPD, pneumonia, CHF, lung injury | No: according to case mix | Partial
Hilbert (1998b) | Adult (n=40) | COPD | No: according to case mix | Partial
Afessa (1999) | Adult (n=118) | COPD, asthma, pneumonia, CHF, acute lung injury, hemodynamic instability, neuromuscular | Yes | Fully blinded
Engoren (1999) | Adult (n=82) | Cardiac bypass surgery | No: according to case mix | Likely unblinded
Rady (1999) | Adult (n=11,330) | COPD, asthma, CHF, cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Likely unblinded
Jacob (1997) | Adult surgical (n=183) | Post-op | No: according to case mix | Unblinded
Bouachour (1996) | Adult COPD (n=26) | COPD | No: according to case mix | Fully blinded
Jubran (1997) | Adult COPD (n=31) | COPD | No: according to case mix | Partial
Farias (1998) | Pediatric (n=84) | Pneumonia, post-op, neurological, infant RDS | Yes | Fully blinded
Vallverdu (1998) | Adult general (n=217) | COPD, pneumonia, CHF, post-op, neurological, cardiac bypass surgery, cardiac valve surgery, trauma | Yes | Likely unblinded
Combination of: Successful stepwise decrease in level of mechanical support, spontaneous breathing test prior to extubation, and trial of extubation
Author (year) | ICU Population | Diagnoses | Representative Sample | Blinding of Outcome Assessor
Amoateng-Adjepong (1997) | Adult general (n=60) | COPD, pneumonia, CHF, neurological | Yes | Partial
Weaned and successfully extubated at any time
McDonald (1988) | Adult general (n=30) | COPD, pneumonia, CHF, lung injury, hemodynamic instability, postop, neurological, airway protection, cardiac bypass surgery | Yes | Partial
Menzies (1989) | Adult general (n=95) | COPD, asthma, pneumonia, CHF, lung injury, postop, neurological, neuromuscular, cardiac bypass surgery, cardiac valve surgery, congenital heart disease | Yes | Partial
Shikora (1990) | Adult general (n=20) | Postop, cardiac bypass surgery, cardiac valve surgery | Yes | Unblinded
Nava (1994b) | Adult COPD (n=42) | COPD | No: according to case mix | Likely unblinded
Saldias (1996) | Adult postcardiac surgery (n=230) | Post-op, cardiac bypass surgery, cardiac valve surgery, congenital heart disease | Yes | Likely unblinded
Moody (1997) | Adult COPD (n=27) | COPD | No: according to case mix | Partial
Duration of ventilation in COPD patients
Thorens (1995) | Adult general (n = 87) | COPD | No: according to case mix | Fully blinded
Duration of ventilation in cardiac patients
Peters (1979) | Adult postcardiac surgery (n=49) | Cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Partial
Kanter (1986) | Pediatric (n=140) | Cardiac valve surgery, congenital heart disease | No: according to case mix | Likely unblinded
Ingersoll (1991) | Adult general (n=47) | Neuromuscular, cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Likely unblinded
Goodnough-Hanneman (1994) | Adult postcardiac surgery (n=162) | Cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Likely unblinded
Arom (1995) | Adult general (n=645) | COPD, cardiac bypass surgery | No: according to case mix | Likely unblinded
Habib (1996) | Adult general (n=507) | COPD, CHF, cardiac bypass surgery | No: according to case mix | Likely unblinded
Bando (1997) | Adult general (n=586) | CHF, cardiac bypass surgery, cardiac valve surgery | Yes | Partial
Doering (1997) | Adult postcardiac surgery (n=62) | Cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Unblinded
Doering (1998) | Adult general (n=116) | COPD, cardiac bypass surgery | Yes | Partial
London (1998) | Adult postcardiac surgery (n=299) | COPD, postop, neurological, cardiac bypass surgery, cardiac valve surgery | No: according to case mix | Likely unblinded

Evidence Table 13. Results of individual observational studies of weaning predictors

Author, Year | Number of Patients | Outcome | Predictor | Predictive Power | P Value
Oh, 1991 | 20 | successful [image] mechanical support | weight CHF/pulmonary edema COPD/asthma oxygen consumption age sex (proportion female) | mean ± sd of success: 56.52 ± 9.43 mean ± sd of failure: 54.24 ± 9.79 sensitivity: 92.3 specificity: 14.3 sensitivity: 92.3 specificity: 28.6 mean ± sd of success: 233.31 ± 58.96 mean ± sd of failure: 205.43 ± 44.29 mean ± sd of success: 51.46 ± 17.88 mean ± sd of failure: 67.57 ± 6.8 sensitivity: 23.1 specificity: 57.1
Linton, 1994 | 27 | successful [image] mechanical support | minute ventilation respiratory rate tidal volume P_0.1_ peak inspiratory pressure PaCO_2_ PaO_2_ vital capacity end tidal CO_2_ | median of success: 8.8 median of failure: 8.1 median of success: 14.0 median of failure: 12.0 median of success: 542 median of failure: 602 median of success: 0.46 median of failure: 2.30 median of success: 23.9 median of failure: 31.7 median of success: 4.25 median of failure: 4.55 median of success: 20.5 median of failure: 12.1 median of success: 1100 median of failure: 900 median of success: 3.61 median of failure: 3.91
Stroetz, 1995 | 31 | successful [image] mechanical support -PS | heart rate mean blood pressure respiratory rate VD/V_T_ = dead space severity of obstruction Vp10 PI_max_ compliance dyspnea Borg scale SaO_2_ PaO_2_/FiO_2_ end tidal CO_2_ clinical prediction of success age | mean ± se of success: 89.6 ± 10.2 mean ± se of failure: 89.9 ± 15.8 mean ± se of success: 89.2 ± 14 mean ± se of failure: 88.6 ± 14.4 mean ± se of success: 14.7 ± 3.4 mean ± se of failure: 19.8 ± 5 mean ± se of failure: 0.64 ± 0.32 mean of success: 0.6 mean of failure: 0.54 mean ± se of success: 42 ± 0.2 mean ± se of failure: 28 ± 0.22 mean ± se of success: 0.08 ± 0.04 mean ± se of failure: 0.05 ± 0.02 mean ± se of success: 9.7 ± 2.4 mean ± se of failure: 9.3 ± 2.6 mean ± se of success: 97.6 ± 1.8 mean ± se of failure: 98 ± 2.2 mean ± se of success: 288 ± 86 mean ± se of failure: 237 ± 116 mean ± se of success: 33.5 ± 8.2 mean ± se of failure: 34.9 ± 7.4 sensitivity: 35 specificity: 79 mean ± se of success: 68 ± 8 mean ± se of failure: 65 ± 10 | >0.05 >0.05 >0.05 >0.05 >0.05 >0.05 >0.05 >0.05 >0.05 >0.05
Rivera, 1997 | 40 | successful [image] mechanical support - PS - IMV - other | minute ventilation <10 respiratory rate <22 tidal volume rapid shallow breathing index <65 P_0.1_ <4.5 pressure time product - threshold: 275 Paw mean dynamic compliance intrinsic PEEP extrinsic PEEP total positive end expiratory pressure inspiratory time/total respiratory cycle | sensitivity: 90 specificity: 50 sensitivity: 84 specificity: 76 mean ± sd of success: 0.41 ± 0.1 mean ± sd of failure: 0.38 ± 0.09 sensitivity: 90 specificity: 80 sensitivity: 100 specificity: 100 sensitivity: 100 specificity: 80 mean ± sd of success: 8.9 ± 4.7 mean ± sd of failure: 10.4 ± 4.6 mean ± sd of success: 81 ± 34 mean ± sd of failure: 72 ± 24 mean ± sd of success: 1.6 ± 0.8 mean ± sd of failure: 5.8 ± 2.4 mean ± sd of success: 2.5 ± 0.3 mean ± sd of failure: 3 ± 0.9 mean ± sd of success: 6.9 ± 2.3 mean ± sd of failure: 8.9 ± 2.7 mean ± sd of success: 37 ± 7 mean ± sd of failure: 42 ± 5 | <0.001 <0.02
Hilberman, 1976 | 124 | successful discontinuation - T-piece | duration mechanical ventilation (hours) mean blood pressure VD/VT = dead space vital capacity in cc/kg vital capacity % predicted VC % predicted FeV_1_ negative inspiratory force inspiratory resistance compliance PaO_2_ pH PaCO_2_ DLCO% cardiac index before bypass | mean ± sd of success: 13.4 ± 11.5 mean ± sd of failure: 23.7 ± 26.9 mean ± sd of success: 87.4 ± 29.6 mean ± sd of failure: 80.2 ± 14.7 mean ± sd of success: 0.53 ± 0.36 mean ± sd of failure: 0.52 ± 0.21 mean ± sd of success: 18.3 ± 7.2 mean ± sd of failure: 11.9 ± 4 mean ± sd of success: 1.3 ± 0.63 mean ± sd of failure: 0.79 ± 0.3 mean ± sd of success: 90.7 ± 13.7 mean ± sd of failure: 71.3 ± 21.9 mean ± sd of success: 75.4 ± 9.3 mean ± sd of failure: 75.8 ± 9.8 mean ± sd of success: 30.7 ± 8.8 mean ± sd of failure: 24.3 ± 9.4 mean ± sd of success: 7.2 ± 2.7 mean ± sd of failure: 9.1 ± 2.6 mean ± sd of success: 0.05 ± 0.01 mean ± sd of failure: 0.04 ± 0.02 mean ± sd of success: 364 ± 80 mean ± sd of failure: 243 ± 93 mean ± sd of success: 7.47 ± 0.06 mean ± sd of failure: 7.46 ± 0.07 mean ± sd of success: 35.2 ± 4.9 mean ± sd of failure: 36.6 ± 7.6 mean ± sd of success: 98.9 ± 1.7 mean ± sd of failure: 104.6 ± 21.3 mean ± sd of success: 2.6 ± 0.8 mean ± sd of failure: 2.1 ± 0.6 | 0.07 0.11 0.84 <0.01 <0.01 <0.01 0.88 0.01 <0.01 0.02 0.29 0.67 0.37 0.34 0.03
Kennedy, 1977 | 20 | successsful discontinuation assessment - T-piece | heart rate pH PaCO_2_ cardiac index left atrial pressure | mean ± se of success: 97 ± 9 mean ± se of failure: 89 ± 4 mean ± se of success: 7.44 ± 0.02 mean ± se of failure: 7.47 ± 0.02 mean ± se of success: 36 ± 1 mean ± se of failure: 40 ± 2 mean ± se of success: 3.4 ± 0.4 mean ± se of failure: 2.5 ± 0.2 mean ± se of success: 9 ± 3 mean ± se of failure: 14 ± 2 | <0.05
Jabour, 1991 | 38 | successsful discontinuation assessment - other | minute ventilation, expressed in ml/kg respiratory rate VE/V_T_ tidal volume expressed in ml/kg PI_max_ Pbreath/NIP pbreath pressure time index dynamic characteristics PaCO_2_ weaning index (PTI x VE/V_t_) inspiratory time/total respiratory cycle sex (proportion female) | mean ± sd of success: 136 ± 39 mean ± sd of failure: 185 ± 53 mean ± sd of success: 26.2 ± 8.3 mean ± sd of failure: 30.3 ± 7.5 mean ± sd of success: 25 ± 11 mean ± sd of failure: 42 ± 16 mean ± sd of success: 5.9 ± 1.7 mean ± sd of failure: 4.8 ± 1.7 mean ± sd of success: 49 ± 11 mean ± sd of failure: 35 ± 15 mean ± sd of success: 0.31 ± 0.1 mean ± sd of failure: 0.39 ± 0.14 mean ± sd of success: 14.5 ± 4.4 mean ± sd of failure: 12.7 ± 4.9 mean ± sd of success: 0.12 ± 0.03 mean ± sd of failure: 0.17 ± 0.07 mean ± sd of success: 26.5 ± 5.5 mean ± sd of failure: 26 ± 6.3 mean ± sd of success: 41.7 ± 13.1 mean ± sd of failure: 48.6 ± 8.7 sensitivity: 95 specificity: 96 mean ± sd of success: 0.4 ± 0.06 mean ± sd of failure: 0.43 ± 0.08 sensitivity: 43.8 specificity:50 | <0.005 <0.001 <0.05 <0.005 <0.05 <0.02
Sassoon, 1993 | 45 | successsful discontinuation assessment - CPAP | minute ventilation <12 respiratory rate <38 tidal volume >325 rapid shallow breathing occlusion pressure index <450 rapid shallow breathing index <100 PI_max_ >20 P_0.1_ <5.5 effective inspiratory impedance <10 | sensitivity: 40 specificity: 50 sensitivity: 97 specificity: 30 sensitivity: 94 specificity: 40 sensitivity: 97 specificity: 60 sensitivity: 97 specificity: 40 sensitivity: 91 specificity: 30 sensitivity: 97 specificity: 40 sensitivity: 89 specificity: 40
Frutos, 1995 | 73 | successsful discontinuation assessment - T-piece | admission APACHE duration of mechanical ventilation (days) COPD/asthma coma heart rate systolic blood pressure respiratory rate tidal volume expressed in ml/kg negative inspiratory force pH age | mean ± sd of success: 19.1 ± 7 mean ± sd of failure: 17.6 ± 7 mean ± sd of success: 6 ± 5.1 mean ± sd of failure: 11.4 ± 5 sens: 76.2 spec: 30 sens: 92.1 spec: 10 mean ± sd of success: 94.1 ± 17.7 mean ± sd of failure: 101.8 ± 11.1 mean ± sd of success: 132.6 ± 23.5 mean ± sd of failure: 147 ± 21 mean ± sd of success: 24.1 ± 5.3 mean ± sd of failure: 30.4 ± 5.5 mean ± sd of success: 6.8 ± 1.8 mean ± sd of failure: 6.6 ± 1.9 mean ± sd of success: 34.6 ± 13.9 mean ± sd of failure: 31.7 ± 19.9 mean ± sd of success: 7.41 ± 0.04 mean ± sd of failure: 7.41 ± 0.03 mean ± sd of success: 58.6 ± 18.7 mean ± sd of failure: 46 ± 24.2 | 0.53 <0.05 0.2 0.1 <0.01 0.7 0.62 0.99 0.13
Chatila, 1996b | 100 | successsful discontinuation assessment | minute ventilation <15 minute volume at time 0 <10 l/min rapid shallow breathing index <100 negative inspiratory force <20 negative inspiratory force <30 | sens: 97 spec: 11 sens: 79 spec: 32 sens: 98 spec: 59 sens: 90 spec: 26 sens: 67 spec: 69
Dojat, 1996 | 38 | successsful discontinuation assessment - T-piece | admission SAPS <15 duration mechanical ventilation (hours) - threshold: 10 respiratory rate <30 tidal volume >325 successful 2-hour T-piece trial rapid shallow breathing index <100 negative inspiratory force <-25 Knowledge-based system | sens: 76.5 spec: 33.3 sens: 70.6 spec: 61.9 sens: 100 spec: 76.2 sens: 52.9 spec: 76.2 sens: 100 spec: 76 sens: 94.1 spec: 81 sens: 94.1 spec: 23.5 sens: 100 spec: 90.5
Saura, 1996b | 30 | successsful discontinuation assessment - CPAP | respiratory rate tidal volume PaO_2_ pH PaCO_2_ end tidal CO_2_ | mean ± se of success: 21 ± 1 mean ± se of failure: 23 ± 2 mean ± se of success: 450 ± 20 mean ± se of failure: 440 ± 30 mean ± se of success: 97 ± 6 mean ± se of failure: 102 ± 11 mean ± se of success: 7.47 ± 0.01 mean ± se of failure: 7.46 ± 0.02 mean ± se of success: 38 ± 2 mean ± se of failure: 38 ± 6 mean ± se of success: 33 ± 1 mean ± se of failure: 35 ± 4
Chao, 1997 | 174 | successsful discontinuation assessment - other | patient-ventilator trigger asynchrony | sensitivity: 96.7 specificity: 19.3
Del Rosario, 1997 | 49 | successsful discontinuation assessment - T -peice | duration of mechanical ventilation (d) heart rate mean blood pressure minute ventilation respiratory rate tidal volume rapid shallow breathing index PI_max_ P_0.1_ inspiratory flow rate (V_t_/T_i_) intrinsic PEEP inspiratory time/total respiratory cycle age | mean ± sd of success: 6.8 ± 7.3 mean ± sd of failure: 13.5 ± 21.1 mean ± se of success: 100.1 ± 2.3 mean ± se of failure: 94.4 ± 4.3 mean ± se of success: 96.2 ± 2.8 mean ± se of failure: 82.9 ± 4.3 mean ± se of success: 12.8 ± 0.6 mean ± se of failure: 13.9 ± 1.6 mean ± se of success: 25.1 ± 1.1 mean ± se of failure: 35.2 ± 3.4 mean ± se of success: 530 ± 28 mean ± se of failure: 436 ± 62 mean ± se of success: 54.5 ± 4.4 mean ± se of failure: 112.7 ± 27.3 mean ± se of success: 43.4 ± 3.4 mean ± se of failure: 33.2 ± 4.4 mean ± se of success: 3.2 ± 0.2 mean ± se of failure: 5.2 ± 1.3 mean ± se of success: 0.56 ± 0.02 mean ± se of failure: 0.59 ± 0.07 mean ± se of success: 2 ± 0.4 mean ± se of failure: 2 ± 0.5 mean ± se of success: 0.39 ± 0.01 mean ± se of failure: 0.39 ± 0.02 mean ± sd of success: 63.1 ± 10 mean ± sd of failure 72 ± 7 | <0.005
Delooz, 1976 | 41 | successsful discontinuation assessment | heart rate mean blood pressure gross alveolar ventilation minute ventilation respiratory rate tidal volume VD/V_t_ physiologic shunt PAO_2_PaO_2_ PaO_2_ pH CaO_2_CvO_2_ PaCO_2_ cardiac index right atrial pressure left atrial pressure pulmonary artery pressure systemic vascular resistance index pulmonary vascular resistance index | mean ± sd of success: 96 ± 14 mean ± sd of failure: 92 ± 26 mean ± sd of success: 85.7 ± 13.9 mean ± sd of failure: 84.3 ± 15 mean ± sd of success: 229 ± 61.1 mean ± sd of failure: 160.8 ± 42.7 mean ± sd of success: 5.451 ± 1.468 mean ± sd of failure: 4.671 ± 1.224 mean ± sd of success: 25.8 ± 6.6 mean ± sd of failure: 29.5 ± 6.7 mean ± sd of success: 469 ± 151 mean ± sd of failure: 371 ± 111 mean ± sd of success: 154 ± 51.3 mean ± sd of failure: 153.2 ± 57.2 mean ± sd of success: 0.11 ± 0.05 mean ± sd of failure: 0.12 ± 0.04 mean ± sd of success: 208 ± 75 mean ± sd of failure: 226 ± 71 mean ± sd of success: 200 ± 84 mean ± sd of failure: 180 ± 74 mean ± sd of success: 7.41 ± 0.04 mean ± sd of failure: 7.38 ± 0.05 mean ± sd of success: 6.7 ± 1.3 mean ± sd of failure: 6.5 ± 2.4 mean ± sd of success: 38 ± 3.4 mean ± sd of failure: 41.7 ± 6.9 mean ± sd of success: 2.47 ± 0.67 mean ± sd of failure: 2.57 ± 1.7 mean ± sd of success: 5.2 ± 4.2 mean ± sd of failure: 11 ± 6.2 mean ± sd of success: 8.2 ± 3.2 mean ± sd of failure: 10.8 ± 3.8 mean ± sd of success: 24 ± 11.6 mean ± sd of failure: 31.1 ± 13.8 mean ± sd of success: 1833 ± 677 mean ± sd of failure: 1904 ± 825 mean ± sd of success: 507 ± 287 mean ± sd of failure: 810 ± 648
Tahvanainen, 1983 | 47 | successful extubation - 24.1-48 h | duration of mechanical ventilation heart rate mean blood pressure maximum voluntary ventilation mean minute ventilation respiratory rate tidal volume VD/V_t_ = dead space vital capacity PI_max_ SaO_2_ PaO_2_ pH VCO_2_ VO_2_ vent postoperative hemoglobin age | mean ± se of success: 4.7 ± 0.5 mean ± se of failure: 6 ± 1.2 mean ± se of success: 98 ± 2.9 mean ± se of failure: 91.9 ± 3.2 mean ± se of success: 96.9 ± 2.4 mean ± se of failure: 99.2 ± 7.1 mean ± se of success: 12.6 ± 0.5 mean ± se of failure: 11.5 ± 1.2 mean ± se of success: 6.16 ± 0.55 mean ± se of failure: 5.96 ± 0.66 mean ± se of success: 23.6 ± 1.2 mean ± se of failure: 19.6 ± 2 mean ± se of success: 270 ± 20 mean ± se of failure: 310 ± 30 mean ± se of success: 42 ± 2 mean ± se of failure: 46 ± 4 mean ± sd of success: 0.8 ± 0.05 mean ± sd of failure: 0.76 ± 0.09 mean ± se of success: 35.7 ± 1.6 mean ± se of failure: 39 ± 1.4 mean ± se of success: 96 ± 0.5 mean ± se of failure: 95.6 ± 0.3 mean ± se of success: 93.6 ± 3.6 mean ± se of failure: 78.8 ± 8.3 mean ± se of success: 7.43 ± 0.01 mean ± se of failure: 7.41 ± 0.02 mean ± se of success: 144 ± 7 mean ± se of failure: 145 ± 9 mean ± se of success: 161 ± 8 mean ± se of failure: 174 ± 13 mean ± se of success: 11.9 ± 0.2 mean ± se of failure: 11 ± 0.4 mean ± se of success: 52.6 ± 2.4 mean ± se of failure: 52.9 ± 5.1 | 0.318 0.32 0.575 0.384 0.805 0.135 0.356 0.332 0.71 0.339 0.575 0.072 0.272 0.943 0.492 0.082 0.976
Adderley, 1987 | 28 | successful extubation | leak test in neonates | sensitivity: 75 specificity: 62.5
Kline, 1987 | 50 | successful extubation - 24.1-48 h | pneumonia postcardiac resuscitation endocarditis post heart surgery postabdominal surgery postthoracic surgery lung cancer COPD/asthma respiratory rate tidal volume PI_max_ change in intrapleural pressure change in intrapleural pressure/NIF change in P_t_/NIF - threshold: 0.4 inspiratory resistance dynamic elastance | sensitivity: 96.6 specificity: 0 sensitivity: 96.6 specificity: 9.5 sensitivity: 96.6 specificity: 4.8 sensitivity: 58.6 specificity: 19 sensitivity: 79.3 specificity: 14.3 sensitivity: 93.1 specificity: 14.3 sensitivity: 96.6 specificity: 0 sensitivity: 82.8 specificity: 28.6 mean ± sd of success: 21.5 ± 4.8 mean ± sd of failure: 22.7 ± 5.4 mean ± sd of success: 0.34 ± 0.08 mean ± sd of failure: 0.4 ± 0.08 mean ± sd of success: 36.1 ± 10.1 mean ± sd of failure: 29 ± 7.6 mean ± sd of success: 11.2 ± 2.9 mean ± sd of failure: 15.2 ± 4.5 mean ± sd of success: 0.32 ± 0.07 mean ± sd of failure: 0.53 ± 0.1 sensitivity: 93.1 specificity: 100 mean ± sd of success: 9.1 ± 3.5 mean ± sd of failure: 9.7 ± 6.3 mean ± sd of success: 23.7 ± 8.7 mean ± sd of failure: 27.7 ± 10.1
Fisher, 1992 | 72 | successful extubation - 12.1-24 h | cuff leak test | sensitivity: 88.7 specificity: 100
Ochiai, 1993 | 38 | successful extubation - 12.1-24 h | weight minute ventilation adjusted for weight respiratory rate tidal volume expressed in ml/kg VD/V_t_ % predicted VC % predicted FeV_1_ inspiratory flow rate (V_t_/T_i_) PaO_2_ pH PaCO_2_ end tidal CO_2_ inspiratory time/total respiratory cycle CO_2_ produced (VCO_2_) age sex (proportion female) | mean ± sd of success: 55.5 ± 6.4 mean ± sd of success: 147.2 ± 49.4 mean ± sd of failure: 140.3 ± 48.8 mean ± sd of success: 14.4 ± 2.9 mean ± sd of failure: 14.5 ± 5.6 mean ± sd of success: 9.67 ± 2.94 mean ± sd of failure: 10.08 ± 1.97 mean ± sd of success: 36.6 ± 5.1 mean ± sd of failure: 33.4 ± 8.3 mean ± sd of success: 95.9 ± 18.7 mean ± sd of failure: 105.7 ± 10.7 mean ± sd of success: 76.1 ± 6.7 mean ± sd of failure: 71.9 ± 5.2 mean ± sd of success: 7.97 ± 2.69 mean ± sd of failure: 8.46 ± 1.47 mean ± sd of success: 124.4 ± 22 mean ± sd of failure: 119.2 ± 26.9 mean ± sd of success: 7.41 ± 0.03 mean ± sd of failure: 7.43 ± 0.05 mean ± sd of success: 39.7 ± 4 mean ± sd of failure: 39.1 ± 6.3 mean ± sd of success: 36.8 ± 3.9 mean ± sd of failure: 37.6 ± 6.4 mean ± sd of success: 0.3 ± 0.06 mean ± sd of failure: 0.28 ± 0.09 mean ± sd of success: 4.7 ± 1.3 mean ± sd of failure: 4.6 ± 1.1 mean ± sd of success: 60.9 ± 8.1 mean ± sd of failure: 62.6 ± 7.3 sensitivity: 15.8 specificity: 89.5
Yang, 1993 | 31 | successful extubation - 12.1-24 h | neuromuscular disorder pneumonia ARDS CHF/pulmonary edema minute ventilation minute ventilation <15 respiratory rate respiratory rate <38 tidal volume tidal volume >325 rapid shallow breathing <100 AND NIP/PI_max_ <0.03 rapid shallow breathing index rapid shallow breathing index <100 Negative inspiratory force PI_max_ - threshold: 15 NIP/ PI_max_ NIP/PI_max_ <0.3 age sex (proportion female) | sensitivity: 62.5 specificity: 20 sensitivity: 81.3 specificity: 20 sensitivity: 93.8 specificity: 20 sensitivity: 81.3 specificity: 6.7 mean ± se of success: 13 ± 0.67 mean ± se of failure: 10.64 ± 1.26 sensitivity: 81 specificity: 20 mean ± se of success: 28 ± 1.94 mean ± se of failure: 36.93 ± 2.92 sensitivity: 88 specificity: 47 mean ± se of success: 0.497 ± 0.053 mean ± se of failure: 0.29 ± 0.028 sensitivity: 100 specificity: 67 sensitivity: 81 specificity: 93 mean ± se of success: 65.26 ± 7.11 mean ± se of failure: 143.3 ± 15.03 sensitivity: 94 specificity: 73 mean ± se of success: 11.48 ± 1.25 mean ± se of failure: 14.32 ± 2.31 mean ± se of success: 47.77 ± 4.48 mean ± se of failure: 40.16 ± 4.55 sensitivity: 100 specificity: 13 mean ± se of success: 0.26 ± 0.03 mean ± se of failure: 0.36 ± 0.04 sensitivity: 75 specificity: 67 mean ± sd of success: 55 ± 3.5 mean ± sd of failure: 59 ± 5.3 sensitivity: 31.3 specificity: 60 | 0.11 <0.05 <0.01 <0.01 0.28 0.24 <0.05
Lee, 1994 | 52 | successful extubation - 12.1-24 h | duration of mechanical ventilation (d) rapid shallow breathing index <105 age | mean ± sd of success: 4.6 ± 3.9 mean ± sd of failure: 9.6 ± 6.8 sensitivity: 72 specificity: 11 mean ± sd of success: 55.2 ± 18.8 mean ± sd of failure: 52.8 ± 19.6 | 0.004 0.73
Epstein, 1995 | 94 | successful extubation - other | rapid shallow breathing index <100 | sensitivity: 92 specificity: 22
DeHaven, 1996 | 589 | successful extubation | respiratory rate <30 | sensitivity: 82.1 specificity: 17.4
el-Khatib, 1996 | 50 | successful extubation - 24.1-48 h | NIP/PI_max_ NIP/PI_max_ <0.3 NIP/PI_max_ <0.4 sex (proportion female) | mean ± sd of success: 0.36 ± 0.14 mean ± sd of failure: 0.45 ± 0.1 sensitivity: 33.3 specificity: 90.9 sensitivity: 62 specificity: 63 sensitivity: 46.2 specificity: 54.5
Ely, 1996 | 300 | successful extubation - 24.1-48 hrs | pass daily screening tests | sens: 88 spec: 67
Epstein, 1996 | 218 | successful extubation - other | rapid shallow breathing index <100 sex (proportion female) | sensitivity: 88.6 specificity: 23.5 sensitivity: 38.6 specificity: 67.6
Khan, 1996 | 213 | successful extubation - >48hrs | duration of mechanical ventilation (d) respiratory rate standardized to age - threshold: 1 - threshold: 2 respiratory rate V_t_/T_i_ - threshold: 14 - threshold: 7 tidal volume tidal volume expressed in ml/kg - threshold: 6 - threshold: 4 RSBI standardized to body weight <8 - threshold: 4 Negative inspiratory force PI_max_ - threshold: 5 - threshold: 10 NIP/PI_max_ peak inspiratory pressure - threshold: 25 - threshold: 30 inspiratory flow rate dynamic compliance Cdyn standardized to body weight - threshold: 0.9 - threshold: 0.4 FiO_2_ PaO_2_ pH HCO_3_ PaCO_2_ oxygenation index oxygenation index - threshold: 1.5 - threshold: 5 CROP Index - threshold: 0.2 - threshold: 0.5 age | mean ± se of success: 5 ± 0.4 mean ± se of failure: 5.2 ± 0.6 sensitivity: 70.5 specificity: 33.3 sensitivity: 42.8 specificity: 66.7 beta P value: 0.768 sensitivity: 36.3 specificity: 81.3 sensitivity: 87.7 specificity: 25 beta P value: 0.01 sensitivity: 48.5 specificity: 71.9 specificity: 28.1 sensitivity: 63.8 specificity: 55.9 beta P value: 0.34 sensitivity: 24.1 specificity: 76.5 beta P value: 0.34 beta P value: 0.412 beta P value: 0.536 sensitivity: 8.2 specificity: 97.1 beta P value: 0.012 sensitivity: 98.2 specificity: 11.8 beta P value: 0.012 beta P value: 0.791 sensitivity: 44.3 specificity: 82.4 beta P value: 0.001 sensitivity: 77 specificity: 47.1 beta P value: 0.001 beta P value: 0.004 beta P value: 0.116 sensitivity: 5.9 specificity: 97.1 sensitivity: 18.2 specificity: 85.3 beta P value: 0.018 mean ± se of success: 105.3 ± 4.3 mean ± se of failure: 99.8 ± 6.8 mean ± se of success: 7.43 ± 0.01 mean ± se of failure: 7.41 ± 0.38 mean ± se of success: 26.4 ± 0.3 mean ± se of failure: 26.5 ± 0.8 mean ± se of success: 40.5 ± 0.6 mean ± se of failure: 42.3 ± 1.4 beta P value: 0.012 sensitivity: 21 specificity: 84.8 sensitivity: 93 specificity: 18.2 sensitivity: 55.8 specificity: 46.9 beta P value: 0.41 sensitivity: 18.6 specificity: 84.4 beta P value: 0.41 mean ± se of success: 3.05 ± 0.35 mean ± se of failure: 4.4 ± 1.01 | 0.8 0.768 0.01 0.34 0.34 0.412 0.536 0.012 0.012 0.791 <0.001 <0.001 0.004 0.116 0.018 0.6 0.9 0.23 0.012 0.41 0.41 0.14
Leitch, 1996 | 163 | successful extubation -12.1-24 h | minute volume <10 prior to CPAP/PS vital capacity <10 rapid shallow breathing index <100 PI_max_ >20 | sensitivity: 50 specificity: 67 sensitivity: 72 specificity: 0 sensitivity: 96.3 specificity: 0 sensitivity: 97 specificity: 0
Mergoni, 1996 | 51 | successful extubation -12.1-24 H | minute ventilation < 10 respiratory rate <30 rapid shallow breathing index <105 PI_max_ >30 P_0.1_/MIP <0.14 inspiratory quotient k(TV/C_dyo_)/MIP X T_i_/T_x_ - threshold: 0.19 weaning index PTI X VE40/V_t_ - threshold: 4 CROP Index - threshold: 13 | sens: 60 spec: 53 sens: 70 spec: 66 sens: 65 spec: 58 sens: 73 spec: 40 sens: 85 spec: 36 sens: 94 spec: 12 sens: 69 spec: 47 spec: 70 sens: 63
Baumeister, 1997 | 47 | successful extubation - 24.1-48 h | pneumonia congential heart disease RSBI standardized to body weight <11 CROP Index standardized to weight - threshold: 0.1 sex (proportion female) | sensitivity: 89.5 specificity: 22.2 sensitivity: 60.5 specificity: 55.6 sensitivity: 78.9 specificity: 77.9 sensitivity: 100 specificity: 100 sensitivity: 47.4 specificity: 55.6
Gologorskii, 1997 | 127 | successful extubation | heart rate minute ventilation respiratory rate tidal volume rapid shallow breathing index negative inspiratory force inspiratory resistance dynamic compliance physiologic shunt PaO_2_ PaO_2_/FiO_2_ pH PaCO_2_ | sens: 79 spec: 58 sens: 66 spec: 66 sens: 70 spec: 72 sens: 73 spec: 75 sens: 84 spec: 83 sens: 68 spec: 62 sens: 74 spec: 77 sens: 77 spec: 80 sens: 80 spec: 61 sens: 74 spec: 61 sens: 86 spec: 46 sens: 84 spec: 54 sens: 70 spec: 55
Krieger, 1997 | 49 | successful extubation > 48 h | duration of mechanical ventilation (d) pneumonia ARDS CHF/pulmonary edema COPD/asthma minute ventilation respiratory rate tidal volume rapid shallow breathing index <105 rapid shallow breathing index <130 PI_max_ peak inspiratory pressure static compliance intrinsic PEEP extrinsic PEEP FiO_2_ PaO_2_/PAO_2_ pH PaCO_2_ age | mean ± sd of success: 5.5 ± 6 mean ± sd of failure: 13 ± 11 sensitivity: 63.2 sensitivity: 89.5 specificity: 9.1 sensitivity: 76.3 specificity: 27.3 sensitivity: 84.2 specificity: 18.2 mean ± sd of success: 6.4 ± 2.5 mean ± sd of failure: 6.1 ± 2.1 mean ± sd of success: 22 ± 7 mean ± sd of failure: 28 ± 5 mean ± sd of success: 0.31 ± 0.13 mean ± sd of failure: 0.22 ± 0.76 sensitivity: 74 specificity: 73 sensitivity: 92 specificity: 57 mean ± sd of success: 43 ± 11 mean ± sd of failure: 35 ± 11 mean ± sd of success: 25 ± 8 mean ± sd of failure: 29 ± 7.5 mean ± sd of success: 0.049 ± 0.014 mean ± sd of failure: 0.04 ± 0.014 mean ± sd of success: 0.53 ± 1.3 mean ± sd of failure: 1.5 ± 2.8 mean ± sd of success: 3.82 ± 1.5 mean ± sd of failure: 4 ± 1.18 mean ± sd of success: 0.4 ± 0.06 mean ± sd of failure: 0.38 ± 0.06 mean ± sd of success: 0.53 ± 0.18 mean ± sd of failure: 0.49 ± 0.16 mean ± sd of success: 7.46 ± 0.05 mean ± sd of failure: 7.44 ± 0.04 mean ± sd of success: 36 ± 7 mean ± sd of failure: 45 ± 7 mean ± sd of success: 79 ± 6 mean ± sd of failure: 80 ± 7 | <0.05 <0.05 <0.05
Hilbert, 1998b | 40 | successful extubation - other | respiratory rate rapid shallow breathing index P_0.1_ effective inspiratory impedance PaO_2_ PaO_2_/FiO_2_ pH HCO_3_ PaCO_2_ age | mean ± sd of success: 24 ± 5 mean ± sd of failure: 25 ± 5 mean ± sd of success: 60 ± 2 mean ± sd of failure: 66 ± 28 mean ± sd of success: 2.4 ± 0.9 mean ± sd of failure: 2.9 ± 0.7 mean ± sd of success: 5.2 ± 1.2 mean ± sd of failure: 6.1 ± 1.3 mean ± sd of success: 59 ± 6 mean ± sd of failure: 60 ± 7 mean ± sd of success: 248 ± 62 mean ± sd of failure: 241 ± 56 mean ± sd of success: 7.42 ± 0.02 mean ± sd of failure: 7.41 ± 0.02 mean ± sd of success: 30 ± 4 mean ± sd of failure: 30 ± 3 mean ± sd of success: 58 ± 6 mean ± sd of failure: 60 ± 7 mean ± sd of success: 68 ± 10 mean ± sd of failure: 69 ± 8
Afessa, 1999 | 118 | successful extubation - other | admission APACHE duration of mechanical ventilation (days) minute ventilation respiratory rate rapid shallow breathing index PI_max_ relative inspiratory effort dynamic compliance static compliance auto-PEEP PaO_2_/FiO_2_ weaning index A + B + G score physician prediction respiraory therapist prediction CROP Index | mean ± sd of success: 11.3 ± 5.2 mean ± sd of failure: 16.9 ± 5.5 mean ± sd of success: 10.7 ± 6.4 mean ± sd of failure: 11.8 ± 7.8 mean ± sd of success: 10.7 ± 3.4 mean ± sd of failure: 9.5 ± 4.2 mean ± sd of success: 27.4 ± 7.8 mean ± sd of failure: 28.5 ± 9.5 mean ± sd of success: 79.2 ± 41.2 mean ± sd of failure: 103 ± 62.3 mean ± sd of success: 60.8 ± 23.7 mean ± sd of failure: 45.3 ± 17.2 sens: 55 spec: 68 mean ± sd of success: 22 ± 7 mean ± sd of failure: 24 ± 7 mean ± sd of success: 35 ± 12 mean ± sd of failure: 37 ± 14 mean ± sd of success: 1 ± 2.3 mean ± sd of failure: 1.5 ± 2.5 mean ± sd of success: 441 ± 115 mean ± sd of failure: 423 ± 125 mean ± sd of success: 5.5 ± 4.4 mean ± sd of failure: 7 ± 4.9 mean ± sd of success: 53.1 ± 13.8 mean ± sd of failure: 48.8 ± 17.6 sens: 62 spec: 65 sens: 55 spec: 62 mean ± sd of success: 36.1 ± 22.7 mean ± sd of failure: 26.5 ± 17 | <0.001 0.357 0.046 0.525 0.062 <0.01 0.289 0.536 0.395 0.511 0.046 0.112 0.013
Engoren, 1999 | 82 | successful extubation | weight duration mechanical ventilation (hours) minute ventilation, expressed in ml/kg minute ventilation tidal volume tidal volume expressed in ml/kg vital capacity in cc/kg negative inspiratory force FiO_2_ PaO_2_ left atrial pressure arterial grafts ejection fraction cardiopulmonary bypass time age | mean ± sd of success: 85 ± 19 mean ± sd of failure: 79 ± 15 median (IQR) of success: 6 (4.7,12.7) median (IQR) of failure: 15.5 (8.2,19.5) mean ± sd of success: 0.09 ± 0.03 mean ± sd of failure: 0.11 ± 0.03 mean ± sd of success: 7.55 ± 2.31 mean ± sd of failure: 8.25 ± 2.48 mean ± sd of success: 533 ± 173 mean ± sd of failure: 457 ± 131 mean ± sd of success: 6.4 ± 1.9 mean ± sd of failure: 5.8 ± 1.3 mean ± sd of success: 15.6 ± 6.2 mean ± sd of failure: 11.5 ± 3.9 mean ± sd of success: 42 ± 8 mean ± sd of failure: 38 ± 10 mean ± sd of success: 0.53 ± 0.08 mean ± sd of failure: 0.61 ± 0.19 mean ± sd of success: 131 ± 41 mean ± sd of failure: 123 ± 52 mean ± sd of success: 20 ± 8 mean ± sd of failure: 20 ± 7 median (IQR) of success: 3 (2,4) median (IQR) of failure: 3 (2,4) mean ± sd of success: 0.55 ± 0.13 mean ± sd of failure: 0.53 ± 0.13 median (IQR) of success: 89 (68,109) median (IQR) of failure: 115 (96,147) mean ± sd of success: 61 ± 12 mean ± sd of failure: 66 ± 11 | <0.05 <0.05 <0.05 <0.05 <0.1 <0.05 <0.05
Rady, 1999 | 11330 | successful extubation - 12.1-24hrs | diabetes hypertension prior myocardial infarction peripheral vascular disease COPD/asthma smoking history creatinine preoperative blood urea nitrogen renal failure mean blood pressure cardiac index right atrial pressure prior cardiac surgery cardiac surgery: valve only cardiac surgery: CABG emergent cardiac surgery cardiac surgery: valve or CABG NYHA class III or IV preoperative intra-aortic balloon pump aortic crossclamp time total bypass time total operating room time hemodynamic instability sex (proportion female) | sens: 78.6 spec: 25.1 sens: 47.1 spec: 41.6 sens: 58.6 spec: 44.3 sens: 78.5 spec: 32.1 sens: 93.6 spec: 11.8 sens: 40.5 spec: 62.4 mean ± sd of success: 1.2 ± 0.7 mean ± sd of failure: 1.4 ± 0.9 mean ± sd of success: 19 ± 10 mean ± sd of failure: 24 ± 16 mean ± sd of success: 74 ± 16 mean ± sd of failure: 78 ± 18 mean ± sd of success: 95 ± 15 mean ± sd of failure: 92 ± 17 mean ± sd of success: 2.6 ± 0.7 mean ± sd of failure: 2.4 ± 0.7 mean ± sd of success: 10 ± 4 mean ± sd of failure: 11 ± 6 sens: 77 spec: 39.8 sens: 69.6 spec: 35.4 sens: 41.5 spec: 40.6 sens: 94.3 spec: 12.3 sens: 88.9 spec: 17.1 sens: 85.8 spec: 23.3 sens: 97.5 spec: 6.7 mean ± sd of success: 73 ± 30 mean ± sd of failure: 86 ± 43 mean ± sd of success: 108 ± 46 mean ± sd of failure: 136 ± 75 mean ± sd of success: 5.2 ± 1.5 mean ± sd of failure: 6.5 ± 3.1 sens: 99.3 spec: 3.6 sens: 28.4 spec: 69.4 | <0.0001 <0.0001 <0.0001 <0.0001 <0.0001 <0.0001 <0.0001 <0.0001 <0.0001
Sahn, 1973 | 100 | successful discontinuation assessment + extubation | minute ventilation <10 Negative inspiratory force >25 | sensitivity: 96.4 specificity: 47.1 sensitivity: 100 specificity: 100
Krieger, 1989 | 269 | successful discontinuation assessment + extubation | duration mechanical ventilation (h) minute ventilation respiratory rate tidal volume PI_max_ PaO_2_ PaO_2_/FiO_2_ pH PaCO_2_ age | mean ± sd of success: 62 ± 98 mean ± sd of failure: 147 ± 144 mean ± sd of success: 7.9 ± 3 mean ± sd of failure: 8.1 ± 3.2 mean ± sd of success: 22 ± 6 mean ± sd of failure: 23 ± 8 mean ± sd of success: 371 ± 149 mean ± sd of failure: 355 ± 140 mean ± sd of success: 38 ± 14 mean ± sd of failure: 32 ± 14 mean ± sd of success: 105 ± 27 mean ± sd of failure: 107 ± 32 mean ± sd of success: 280 ± 86 mean ± sd of failure: 298 ± 115 mean ± sd of success: 7.44 ± 0.05 mean ± sd of failure: 7.42 ± 0.05 mean ± sd of success: 37 ± 5 mean ± sd of failure: 38 ± 7 mean ± sd of success: 80 ± 6 mean ± sd of failure: 80 ± 6 | <0.001 <0.02 <0.05
Saito, 1991 | 23 | successful discontinuation assessment + extubation | P_0.1_ <4.4 | sens: 100 spec: 55.6
Yang, 1991 | 100 | successful discontinuation assessment + extubation | minute ventilation <15 respiratory rate <38 tidal volume >325 tidal volume expressed in ml/kg >4 rapid shallow breathing index <33 rapid shallow breathing index <105 PI_max_ >15 dynamic compliance >22 PaO_2_/PAO_2_ >0.35 CROP Index -threshold: 13 | sensitivity: 78 specificity: 18 sensitivity: 92 specificity: 36 sensitivity: 97 specificity: 54 sensitivity: 94 specificity: 39 sensitivity: 75 specificity: 36 sensitivity: 97 specificity: 64 sensitivity: 100 specificity: 11 sensitivity: 72 specificity: 50 sensitivity: 81 specificity: 29 sensitivity: 81 specificity: 57
Ashutosh, 1992 | 30 | successful discontinuation assessment + extubation | minute ventilation respiratory rate tidal volume negative inspiratory force neural network analysis statistical prediction model | mean ± sd of success: 11.33 ± 4.37 mean ± sd of failure: 10.63 ± 2.4 mean ± sd of success: 22.53 ± 4.84 mean ± sd of failure: 33.27 ± 7.97 mean ± sd of success: 552.73 ± 213.69 mean ± sd of failure: 326.13 ± 99.43 mean ± sd of success: 38.8 ± 10.4 mean ± sd of failure: 21 ± 6.07 sensitivity: 100 specificity: 93.3 sensitivity: 93.3 specificity: 93.3
Gandia, 1992 | 30 | successful discontinuation assessment + extubation | weight minute ventilation <12.5 respiratory rate <35 tidal volume >360 rapid shallow breathing index rapid shallow breathing index <96 PI_max_ >23 P_0.1_/MIP <0.14 at 15 min P_0.1_/MIP <0.14 at 60 min P_0.1_/MIP <0.14 at 120 min P_0.1_ <3.4 P_0.1_/MIP <0.14 inspiratory effort quotient <0.19 dynamic compliance PaO_2_/PAO_2_ age | mean ± sd of success: 71 ± 16 mean ± sd of failure: 68 ± 10 sensitivity: 75 specificity: 64 sensitivity: 75 specificity: 82 sensitivity: 58 specificity: 75 mean ± sd of success: 71 ± 21 mean ± sd of failure: 103 ± 15 sensitivity: 83 specificity: 82 sensitivity: 75 specificity: 82 sensitivity: 82 specificity: 83 sensitivity: 82 specificity: 80 sensitivity: 82 specificity: 100 sensitivity: 75 specificity: 61 sensitivity: 1 specificity: 82 sensitivity: 100 specificity: 82 mean ± sd of success: 30 ± 5 mean ± sd of failure: 25 ± 3 mean ± sd of success: 0.43 ± 0.13 mean ± sd of failure: 0.35 ± 0.1 mean ± sd of success: 55 ± 17 mean ± sd of failure: 59 ± 11 | <0.001 <0.05
Mohsenifar, 1993 | 29 | successful discontinuation assessment + extubation | duration of mechanical ventilation (d) heart rate systolic blood pressure respiratory rate respiratory rate <38 tidal volume tidal volume > 325 rapid shallow breathing index <105 Negative inspiratory force >20 FiO_2_ PaO_2_ gastric intramucosal pH gastric intramucosal PCO_2_ pH >7.3 or change of <0.09 change in gastric intramucosal pH change in gastric intramucosal PaCO_2_ PaCO_2_ age | mean ± sd of success: 6.2 ± 8 mean ± sd of failure: 7 ± 4 mean ± sd of success: 96 ± 18 mean ± sd of failure: 95 ± 17 mean ± sd of success: 128 ± 24 mean ± sd of failure: 140 ± 22 mean ± sd of success: 16 ± 4 mean ± sd of failure: 17 ± 6 sensitivity: 100 specificity: 27 mean ± sd of success: 626 ± 105 mean ± sd of failure: 608 ± 120 sensitivity: 100 specificity: 18 sensitivity: 100 specificity: 27 sensitivity: 100 specificity: 9 mean ± sd of success: 35 ± 8 mean ± sd of failure: 40 ± 7 mean ± sd of success: 95 ± 21 mean ± sd of success: 93 ± 29 mean ± sd of failure 7.45 ± 0.13 mean ± sd of failure: 7.36 ± 0.2 mean ± sd of success: 37 ± 12 mean ± sd of failure: 49 ± 23 sensitivity: 100 specificity: 100 mean of success: 0.01 mean of failure: 0.27 mean of success: 1 mean of failure: 62 mean ± sd of success: 39 ± 7 mean ± sd of failure: 40 ± 14 mean ± sd of success: 69 ± 13 mean ± sd of failure: 61 ± 20 | >0.3 0.3 0.21 >0.3 >0.3 >0.3 >0.3 0.07 0.07 <0.1 <0.1 >0.3 >0.3
Capdevila, 1995 | 67 | successful discontinuation assessment + extubation | weight admission SAPS duration of mechanical ventilation (d) minute ventilation respiratory rate tidal volume vital capacity rapid shallow breathing index rapid shallow breathing index <60 PI_max_ >50 P_0.1_ P_0.1_ <5.0 P_0.1_/MIP P_0.1_/MIP <0.09 Sao_2_ pH inspiratory time inspiratory time/total respiratory cycle age | mean ± sd of success: 69.74 ± 13.13 mean ± sd of failure: 66.33 ± 11.69 mean ± sd of success: 11.08 ± 4.32 mean ± sd of failure: 13.25 ± 3.81 mean ± sd of success: 14.71 ± 13.2 mean ± sd of failure: 12.21 ± 6.31 mean ± sd of success: 12.61 ± 3.75 mean ± sd of failure: 12.45 ± 3.9 mean ± sd of success: 24.16 ± 7.13 mean ± sd of failure: 28.33 ± 3.98 mean ± sd of success: 527 ± 161 mean ± sd of failure: 458 ± 188 mean ± sd of success: 1.21 ± 0.68 mean ± sd of failure: 0.8 ± 0.35 mean ± sd of success: 50 ± 23 mean ± sd of failure: 69 ± 25 sensitivity: 73 specificity: 75 sensitivity: 80 specificity: 41 mean ± sd of success: 3.62 ± 1.35 mean ± sd of failure: 7.38 ± 2.67 sensitivity: 87 specificity: 91 mean ± sd of success: 0.05 ± 0.01 mean ± sd of failure: 0.14 ± 0.04 sensitivity: 98 specificity: 100 mean ± sd of success: 93 ± 3 mean ± sd of failure: 91 ± 4 mean ± sd of success: 7.41 ± 0.03 mean ± sd of failure: 7.38 ± 0.05 mean ± sd of success: 1.12 ± 0.23 mean ± sd of failure: 0.91 ± 0.28 mean ± sd of success: 0.46 ± 0.09 mean ± sd of failure: 0.48 ± 0.18 mean ± sd of success: 48.43 ± 20.23 mean ± sd of failure: 68.83 ± 7.75 | >0.05 >0.05 0.694 0.069 0.067 0.027 0.018 0.001 >0.3 >0.3 >0.3 >0.3 0.07 0.07 <0.01 <0.01 0.001 0.061 0.128 >0.05 >0.05 0.0008
Bouachour, 1996 | 26 | successful discontinuation assessment + extubation | admission SAPS duration mechanical ventilation (h) heart rate systolic blood pressure SaO_2_ PaO_2_ pH HCO_3_ gastric intramucosal pH >7.3 gastric intramucosal PCO_2_ <60d> PaCO_2_ age <40 | mean ± sd of success: 16 ± 3 mean ± sd of failure: 16 ± 4 mean ± sd of success: 8 ± 4 mean ± sd of failure: 11 ± 7 mean ± sd of success: 85 ± 13 mean ± sd of failure: 103 ± 22 mean ± sd of success: 134 ± 15 mean ± sd of failure: 115 ± 17 mean ± sd of success: 96 ± 2 mean ± sd of failure: 97 ± 1 mean ± sd of success: 87 ± 20 mean ± sd of failure: 88 ± 13 mean ± sd of success: 7.48 ± 0.04 mean ± sd of failure: 7.45 ± 0.06 mean ± sd of success: 33 ± 4 mean ± sd of failure: 32 ± 3 sensitivity: 100 specificity: 100 sensitivity: 95 specificity: 100 mean ± sd of success: 44 ± 6 mean ± sd of failure: 48 ± 7 sensitivity: 100 specificity: 0
Jacob, 1997 | 183 | successful discontinuation assessment + extubation | minute ventilation <10 rapid shallow breathing index <100 negative inspiratory force <20 | sens: 76 spec: 40 sens: 97 spec: 33 sens: 96 spec: 7
Jubran, 1997 | 31 | successful discontinuation assessment + extubation | duration of mechanical ventilation (d) minute ventilation respiratory rate tidal volume/inspiratory time tidal volume rapid shallow breathing index PI_max_ pressure time product inspiratory resistance dynamic elastance intrinsic PEEP PaO_2_ pH PaCO_2_ inspiratory time inspiratory time/total respiratory cycle expiratory time tension time index age | mean ± sd of success: 10.79 ± 3.26 mean ± sd of failure: 25.12 ± 9.49 mean ± se of success: 7.98 ± 0.71 mean ± se of failure: 9.06 ± 1.32 mean ± se of success: 22.7 ± 1.6 mean ± se of failure: 34.5 ± 2.6 mean ± se of success: 329 ± 29 mean ± se of failure: 387 ± 49 mean ± se of success: 373 ± 45 mean ± se of failure: 263 ± 26 mean ± se of success: 75 ± 11 mean ± se of failure: 158 ± 20 mean ± se of success: 46.3 ± 3.1 mean ± se of failure: 41.6 ± 5.3 mean ± se of success: 158 ± 23 mean ± se of failure: 255 ± 59 mean ± se of success: 5.3 ± 1.1 mean ± se of failure: 9 ± 1.7 mean ± se of success: 9.9 ± 1.7 mean ± se of failure: 21.2 ± 3.4 mean ± se of success: 0.7 ± 0.1 mean ± se of failure: 2 ± 0.5 mean ± se of success: 100 ± 5 mean ± se of failure: 93 ± 6 mean ± se of success: 7.44 ± 0.01 mean ± se of failure: 7.43 ± 0.01 mean ± se of success: 41 ± 2 mean ± se of failure: 45 ± 2 mean ± se of success: 1.16 ± 0.09 mean ± se of failure: 0.71 ± 0.04 mean ± se of success: 0.41 ± 0.02 mean ± se of failure: 0.39 ± 0.02 mean ± se of success: 1.68 ± 0.16 mean ± se of failure: 1.29 ± 0.18 mean ± se of success: 0.05 ± 0.01 mean ± se of failure: 0.06 ± 0.01 mean ± sd of success: 70 ± 3.45 mean ± sd of failure: 67.35 ± 1.96 | <0.04 <0.002 0.48 0.17 0.11 <0.01 <0.03 <0.0001
Farias, 1998 | 84 | successful discontinuation assessment + extubation | weight duration of mechanical ventilation (days) minute ventilation, expressed in ml/kg respiratory rate tidal volume expressed in ml/kg >4 V_t_ in ml/kg >6.5 RSBI standardized to body RSBI standardized to body >11 PI_max_ PaO_2_/PAO_2_ PaO_2_/FiO_2_ age | median (IQR) of success: 7.5 (5.5,14.5) median (IQR) of success: 8 (4,13) median (IQR) of failure: 11.9 (8.9,19.6) median (IQR) of success: 245 (180,320) median (IQR) of failure: 227 (143,274) median (IQR) of success: 40 (31,50) median (IQR) of failure: 46 (36,59) sens: 94 spec: 43 median (IQR) of success: 6.8 (4.8,8) median (IQR) of success: 6.5 (4.3,8.7) median (IQR) of failure: 10.5 (8.2,14.3) sens: 86 spec: 48 median (IQR) of success: 45 (86,60) median (IQR) of failure: 37 (33,54) median (IQR) of success: 0.48 (0.4,0.6) median (IQR) of failure: 0.49 (0.46,0.51) median (IQR) of success: 295 (213,377) median (IQR) of failure: 287.6 (250.6,408) median (IQR) of success: 8 (4,33) median (IQR) of failure: 5.1 (3.4,16.4)
Vallverdu, 1998 | 217 | successful discontinuation assessment + extubation | duration of mechanical ventilation (days) minute ventilation respiratory rate tidal volume vital capacity rapid shallow breathing occlusion pressure index rapid shallow breathing index rapid shallow breathing index <100 maximum expiratory pressure PI_max_ P_0.1_ P_0.1_ <4.5 P_0.1_/MIP age | mean ± sd of success: 7 ± 7 mean ± sd of failure: 12 ± 12 mean ± sd of success: 11 ± 10 mean ± sd of failure: 10 ± 3 mean ± sd of success: 24 ± 6 mean ± sd of failure: 29 ± 8 mean ± sd of success: 432 ± 143 mean ± sd of failure: 378 ± 134 mean ± sd of success: 1.63 ± 0.64 mean ± sd of failure: 1.3 ± 0.51 mean ± sd of success: 241 ± 177 mean ± sd of failure: 452 ± 363 mean ± sd of success: 65 ± 30 mean ± sd of failure: 88 ± 44 sens: 90 spec: 36 mean ± sd of success: 53 ± 25 mean ± sd of failure: 37 ± 17 mean ± sd of success: 65 ± 21 mean ± sd of failure: 53 ± 17 mean ± sd of success: 3.6 ± 1.5 mean ± sd of failure: 5 ± 2.4 sens: 75 spec: 55 mean ± sd of success: 0.063 ± 0.032 mean ± sd of failure: 0.103 ± 0.056 mean ± sd of success: 55 ± 17 mean ± sd of failure: 59 ± 15 | <0.001 <0.001 <0.01 <0.001 <0.001 <0.001 <0.001 <0.001 <0.001 <0.001
Thorens, 1995 | 87 | COPD duration of ventilation | nursing index | mean difference P-value: 0.025 | 0.025
Peters, 1979 | 49 | CVICU duration of ventilation | vital capacity FeV_1_ maximum expiratory pressure PI_max_ MMEF 50-75 MMEF 75-85 cardiac surgery: valve only cardiac surgery: CABG cardiac surgery: valve or CABG | mean ± sd of success: 3.2 ± 1.1 mean ± sd of failure: 2.4 ± 0.9 mean ± sd of success: 2.1 ± 0.7 mean ± sd of failure: 1.5 ± 0.6 mean ± sd of success: 68 ± 24 mean ± sd of failure: 47 ± 26 mean ± sd of success: 60 ± 24 mean ± sd of failure: 40 ± 22 mean ± sd of success: 1.8 ± 1 mean ± sd of failure: 1.1 ± 0.6 mean ± sd of success: 0.9 ± 0.5 mean ± sd of failure: 0.5 ± 0.2 sensitivity: 14.3 specificity: 57.1 sensitivity: 71.4 specificity: 71.4 sensitivity: 14.3 specificity: 71.4 | <0.01 <0.01 <0.04 <0.02 <0.01 <0.003
Kanter, 1986 | 140 | CVICU duration of ventilation | study derived predictive index second surgical procedure preoperative mechanical ventilation cardiopulmonary bypass time aortic crossclamp time failed extubation age | sensitivity: 57 specificity: 94.7 beta P value: 0.005 beta P value: 0.05 beta P value: 0.005 beta P value: 0.01 beta P value: 0.005 beta P value: 0.005 | <0.005 <0.05 <0.005 <0.01 <0.005 <0.005
Ingersoll, 1991 | 47 | CVICU duration of ventilation | previous major surgery neuromuscular disorder pneumonia stroke (CVA) diffuse vascular disease COPD/asthma smoking history kyphoscoliosis prior lung surgery FVC % predicted VC FeV_1_ FeV_1_/VC % predicted FeV_1_ dyspnea preoperative length of stay (d) atelectasis cough supraclavicular retraction accessory muscle use | sensitivity: 80 specificity: 33.3 sensitivity: 94.3 specificity: 0 sensitivity: 97.1 specificity: 8.3 sensitivity: 97.1 specificity: 16.7 sensitivity: 68.6 specificity: 16.7 sensitivity: 82.9 specificity: 0 sensitivity: 22.9 specificity: 83.3 sensitivity: 91.4 specificity: 33.3 sensitivity: 94.3 specificity: 8.3 mean ± sd of success: 2.5 ± 0.9 mean ± sd of failure: 2.9 ± 0.9 mean ± sd of success: 59.6 ± 15.3 mean ± sd of failure: 71.9 ± 13.9 mean ± sd of success: 2.1 ± 0.8 mean ± sd of failure: 2.4 ± 1.1 mean ± sd of success: 83.5 ± 11.9 mean ± sd of failure: 80.1 ± 21.1 mean ± sd of success: 65.8 ± 17.9 mean ± sd of failure: 74.8 ± 24.2 sensitivity: 8.6 specificity: 0 mean ± sd of success: 6.3 ± 6.7 mean ± sd of failure: 12.2 ± 10.8 sensitivity: 88.6 specificity: 16.7 sensitivity: 85.7 specificity: 8.3 sensitivity: 97.1 specificity: 0 sensitivity: 97.1 specificity: 0 | <0.05
Goodnough-Hanneman, 1994 | 162 | CVICU duration of ventilaiton | weight duration mechanical ventilation (h) mean blood pressure vital capacity in cc/kg FiO_2_ PaO_2_ pH age sex (proportion female) | mean ± sd of success: 80 ± 15 mean ± sd of failure: 76 ± 15 mean ± sd of success: 11 ± 5 mean ± sd of failure: 88 ± 9 mean ± sd of success: 93 ± 16 mean ± sd of failure: 79 ± 17 mean ± sd of success: 14.2 ± 5 mean ± sd of failure: 11 ± 4 mean ± sd of success: 0.61 ± 0.09 mean ± sd of failure: 0.72 ± 0.17 mean ± sd of success: 191 ± 87 mean ± sd of failure: 181 ± 108 mean ± sd of success: 7.41 ± 0.06 mean ± sd of failure: 7.35 ± 0.08 mean ± sd of success: 61 ± 12 mean ± sd of failure: 66 ± 9 sensitivity: 20.1 specificity: 75 | <0.001 <0.001 0.001 <0.001 0.585 <0.001
Arom, 1995 | 645 | CVICU duration of ventilation | cardiopulmonary bypass time aortic crossclamp time intra-operative bleeding core intra-operative temperature CK-MB peak chest tube drainage | mean ± sd of success: 88.6 ± 33.4 mean ± sd of failure: 96.9 ± 38.1 mean ± sd of success: 47.6 ± 20.6 mean ± sd of failure: 49.5 ± 19.7 mean ± sd of success: 503 ± 265 mean ± sd of failure: 539 ± 226 mean ± sd of success: 32.7 ± 1.7 mean ± sd of failure: 30.6 ± 2.8 mean ± sd of success: 40.46 ± 47.19 mean ± sd of failure: 57.46 ± 99.84 mean ± sd of success: 503 ± 265 mean ± sd of failure: 539 ± 226 | 0.01
Habib, 1996 | 507 | CVICU duration of ventialation | body surface area creatinine preoperative blood urea nitrogen no. of vessels grafted no. of proximal anastomoses postoperative hemoglobin cardiopulmonary bypass time aortic crossclamp time intra-operative bleeding intraoperative fluid balance core intra-operative temperature | mean ± sd of success: 2.01 ± 0.21 mean ± sd of failure: 1.91 ± 0.22 mean ± sd of success: 1.06 ± 0.72 mean ± sd of failure: 1.09 ± 0.68 mean ± sd of success: 14.8 ± 5.2 mean ± sd of failure: 16.1 ± 6.9 mean ± sd of success: 3.02 ± 1.02 mean ± sd of failure: 3.22 ± 0.97 mean ± sd of success: 1.92 ± 0.9 mean ± sd of failure: 2.2 ± 0.87 mean ± sd of success: 7.42 ± 1.61 mean ± sd of failure: 7.18 ± 1.39 mean ± sd of success: 88.2 ± 30.8 mean ± sd of failure: 95.3 ± 34.9 mean ± sd of success: 51.8 ± 19.8 mean ± sd of failure: 54.3 ± 20.6 mean ± sd of success: 273 ± 157 mean ± sd of failure: 244 ± 171 mean ± sd of success: 1179 ± 1010 mean ± sd of failure: 1448 ± 1041 mean ± sd of success: 35.3 ± 1.9 mean ± sd of failure: 34.8 ± 2.2 | <0.001 <0.07 <0.05 <0.04 <0.02 <0.02 <0.05 0.16 0.17 <0.005
Bando, 1997 | 586 | CVICU duration of ventilation | body surface area prior myocardial infarction stroke (CVA) CHF/pulmonary edema current smoking smoking history coma renal insufficiency vital capacity % predicted VC FeV_1_/FVC% FeV_1_ FeV_1_/VC % predicted FeV_1_ dyspnea DLCO DLCO% cardiac index before bypass prior cardiac surgery cardiac surgery: valve only no. of vessels grafted priority operation cardiomegaly (on CXR) left ventricular ejection fraction fractional shortening left ventricular ejection fraction beta blockers cardiopulmonary bypass time aortic crossclamp time new Q-waves bleeding decreased cardiac output CK-MB peak chest tube drainage age | beta P value: 0.657 beta P value: 0.039 beta P value: 0.36 beta P value: 0.001 OR P value: 0.435 beta P value: 0.377 beta P value: 0.001 OR P value: 0.002 beta P value: 0.359 beta P value: 0.406 beta P value: 0.752 beta P value: 0.269 beta P value: 0.508 beta P value: 0.401 beta P value: 0.067 beta P value: 0.598 beta P value: 0.677 beta P value: 0.98 beta P value: 0.001 beta P value: 0.86 beta P value: 0.676 beta P value: 0.005 beta P value: 0.002 beta P value: 0.547 beta P value: 0.279 beta P value: 0.329 beta P value: 0.232 beta P value: 0.96 beta P value: 0.001 beta P value: 0.001 beta P value: 0.001 beta P value: 0.001 beta P value: 0.001 beta P value: 0.001 beta P value: 0.001 beta P value: 0.03 | 0.657 0.039 0.36 <0.001 0.435 0.377 <0.001 0.002 0.359 0.406 0.752 0.269 0.508 0.401 0.067 0.598 0.677 0.98 <0.001 0.86 0.676 0.005 0.002 0.547 0.279 0.329 0.232 0.96 <0.001 <0.001 <0.001 <0.001 <0.001 <0.001 <0.001 0.03
Doering, 1997 | 62 | CVICU duration of ventilation | cardiac surgery: other than just CABG cardiac surgery: CABG age <70 sex (proportion female) | sensitivity: 9.1 specificity: 74.5 sensitivity: 90.9 specificity: 25.5 sensitivity: 90.9 specificity: 52.9 sensitivity: 63.6 specificity: 70.6
Doering, 1998 | 116 | CVICU duration of ventilation | vasoactive drugs | univariate beta: 0.63
London, 1998 | 299 | CVICU duration of ventilation | body surface area FeV_1_ no. of vessels grafted hematocrit platelet count ischemic time total bypass time operating room time operating room time w/o prep time temperature minimum on CPB crystalloid use in operating room colloid use in operating room total calculated fluid fentanyl dose midazolam dose maximum FiO_2_ during anesthesia % bypass time that isoflurane was used temperature isoflurane discontinued time of arrival in SICU temperature on SICU arrival total urine output sex | mean ± sd of success: 1.99 ± 0.2 mean ± sd of failure: 1.98 ± 0.2 mean ± sd of success: 2.8 ± 0.7 mean ± sd of failure: 2.5 ± 0.8 mean ± sd of success: 3.3 ± 1 mean ± sd of failure: 3.2 ± 1 mean ± sd of success: 42 ± 4 mean ± sd of failure: 42 ± 6 mean ± sd of success: 147 ± 45 mean ± sd of failure: 141 ± 47 mean ± sd of success: 74 ± 22 mean ± sd of failure: 84 ± 28 mean ± sd of success: 115 ± 28 mean ± sd of failure: 134 ± 39 mean ± sd of success: 4.9 ± 1 mean ± sd of failure: 5.4 ± 1.3 mean ± sd of success: 5.8 ± 1.1 mean ± sd of failure: 6.3 ± 1.4 mean ± sd of success: 28.5 ± 2.5 mean ± sd of failure: 28 ± 2.9 mean ± sd of success: 2499 ± 800 mean ± sd of failure: 2721 ± 992 mean ± sd of success: 652 ± 497 mean ± sd of failure: 704 ± 619 mean ± sd of success: 2922 ± 1674 mean ± sd of failure: 3015 ± 1992 mean ± sd of success: 35.6 ± 12.4 mean ± sd of failure: 45.5 ± 22 mean ± sd of success: 0.07 ± 0.04 mean ± sd of failure: 0.09 ± 0.06 mean ± sd of success: 1.3 ± 0.8 mean ± sd of failure: 1.3 ± 0.7 mean ± sd of success: 48.4 ± 24.3 mean ± sd of failure: 43.6 ± 25.7 mean ± sd of success: 33.6 ± 3 mean ± sd of failure: 33.1 ± 3.2 mean ± sd of success: 383 ± 200 mean ± sd of failure: 313 ± 220 mean ± sd of success: 36.4 ± 0.7 mean ± sd of failure: 36.6 ± 0.7 mean ± sd of success: 1556 ± 626 mean ± sd of failure: 1847 ± 903 mean ± sd of success: 0 ± 0 mean ± sd of failure: 1.3 ± 0 | 0.72 0.002 0.89 0.18 0.35 0.01 <0.001 0.001 <0.001 0.28 0.16 0.93 0.66 0.002 0.003 0.99 0.15 0.23 0.003 0.05 0.009 0.5

Evidence Table 14. Results of individual observational studies, grouped according to weaning predictors

Observational Study Results: Important Weaning Predictors
Predictor | Outcome | Author, Year | Number of Patients | Predictive Power | Reported P Value
Duration of Mechanical Ventilation Prior to Weaning Hours <10 hours | successful discontinuation assessment successful extunation successful discontinuation assessment + extubation CVICU duration of ventilation successful discontinuation assessment | Hilberman, 1976 Engoren, 1999 Krieger, 1989 Bouachour, 1996 Goodnough-Hanneman, 1994 Dojat, 1996 | 124 82 269 26 162 38 | mean ± sd of success: 13.4 ± 11.5 mean ± sd of failure: 23.7 ± 26.9 median (IQR) of success: 6.0 (4.7, 12.7) median (IQR) of failure: 15.5 (8.2, 19.5) mean ± sd of success: 62 ± 98 mean ± sd of failure: 147 ± 144 mean ± sd of success: 8 ± 4 mean ± sd of failure: 11 ± 7 mean ± sd of success: 11 ± 5 mean ± sd of failure: 88 ± 9 sensitivity: 70.6 specificity: 61.9 | 0.07 <0.05 <0.001 <0.001
Duration of Mechanical Ventilation Prior to Weaning Days | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Frutos, 1995 Del Rosario, 1997 Tahvanainen, 1983 Lee, 1994 Khan, 1996 Krieger, 1997 Afessa, 1999 Mohsenifar, 1993 Capdevila, 1995 Jubran, 1997 Farias, 1998 Vallverdu, 1998 | 73 49 47 52 213 49 118 29 67 31 84 217 | mean ± sd of success: 6.0 ± 5.1 mean ± sd of failure: 11.4 ± 5.0 mean ± sd of success: 6.8 ± 7.3 mean ± sd of failure: 13.5 ± 21.1 mean ± se of success: 4.7 ± 0.5 mean ± se of failure: 6.0 ± 1.2 mean ± sd of success: 4.6 ± 3.9 mean ± sd of failure: 9.6 ± 6.8 mean ± se of success: 5 ± 0.4 mean ± se of failure: 5.2 ± 0.6 mean ± sd of success: 5.5 ± 6 mean ± sd of failure: 13 ± 11 mean ± sd of success: 10.7 ± 6.4 mean ± sd of failure: 11.8 ± 7.8 mean ± sd of success: 6.2 ± 8 mean ± sd of failure: 7 ± 4 mean ± sd of success: 14.71 ± 13.2 mean ± sd of failure: 12.21 ± 6.31 mean ± sd of success: 10.79 ± 3.26 mean ± sd of failure: 25.12 ± 9.49 median (IQR) of success: 8 (4, 13) median (IQR) of failure: 11.9 (8.9, 19.6) mean ± sd of success: 7 ± 7 mean ± sd of failure: 12 ± 12 | <0.05 0.318 0.004 0.8 <0.05 0.357 >0.3 >0.05 <0.001
Minute Ventilation as ml/kg | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Jabour, 1991 Engoren, 1999 Farias, 1998 | 38 82 84 | mean ± sd of success: 136 ± 39 mean ± sd of failure: 185 ± 53 mean ± sd of success: 105 ± 28 mean ± sd of failure: 91 ± 27 median (IQR) of success: 245(180, 320) meidan (IQR) of failure: 227 (143, 274) | <0.005 <0.05
Respiratory Rate | successful [image] mechanical support successful discontinuation assessment successful extubation sucessful discontinuation assessment + extubation | Stroetz, 1995 Frutos, 1995 Saura, 1996b Tahvanainen, 1983 Hilbert, 1998 Afessa, 1999 Krieger, 1989 Ashutosh, 1992 Mohsenifar, 1993 Capdevila, 1995 Jubran, 1997 Farias, 1998 Vallverdu, 1998 | 31 73 30 47 40 118 269 30 29 67 31 84 217 | mean ± se of success: 14.7 ± 3.4 mean ± se of failure: 19.8 ± 5 mean ± sd of success: 24.1 ± 5.3 mean ± sd of failure: 30.4 ± 5.5 mean ± se of success: 21 ± 1 mean ± se of failure: 23 ± 2 mean ± se of success: 23.6 ±1.2 mean ± se of failure: 19.6 ± 2 mean ± sd of success: 24 ± 5 mean ± sd of failure: 25 ± 5 mean ± sd of success: 27.4 ± 7.8 mean ± sd of failure: 28.5 ± 9.5 mean ± sd of success: 22 ± 6 mean ± sd of failure: 23 ± 8 mean ± sd of success: 22.53 ± 4.84 mean ± sd of failure: 33.27 ± 7.97 mean ± sd of success: 16 ± 4 mean ± sd of failure: 17 ± 6 mean ± sd of success: 24.16 ± 7.13 mean ± sd of failure: 28.33 ± 3.98 mean ± se of success: 22.7 ± 1.6 mean ± se of failure: 34.5 ± 2.6 median (IQR) of success: 40 (31,50) median (IQR) of failure: 46 (36,59) mean ± sd of success: 24 ± 6 mean ± sd of failure: 29 ± 8 | <0.05 <0.01 0.135 0.525 >0.3 0.069 <0.001
Respiratory Rate <22 | successful mechanical support | Rivera, 1997 | 40 | sensitivity: 84 specificity: 76
Respiratory Rate <30 | successful discontinuation assessment successful extubation | Dojat, 1996 Mergoni, 1996 | 38 51 | sensitivity: 100 specificity: 76.2 sensitivity: 70 specificity: 66
No cutpoint reported | | Gologorskii, 1997 | 127 | sensitivity: 70 specificity: 72
Respiratory Rate <35 | successful discontinuation assessment + extubation | Gandia, 1992 | 30 | sensitivity: 75 specificity: 82
Respiratory Rate <38 | successful discontinuation assessment + extubation | Yang, 1991 Mohsenifar, 1993 | 100 29 | sensitivity: 92 specificity: 36 sensitivity: 100 specificity: 27
Tidal Volume | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Saura, 1996a Tahvanainen, 1983 Kline, 1987 Yang, 1993 Krieger, 1997 Engoren, 1999 Krieger, 1989 Ashutosh, 1992 Mohsenifar, 1993 Capdevila, 1995 Jubran, 1997 Vallverdu, 1998 | 30 47 50 31 49 82 269 30 29 67 31 217 | mean ± se of success: 450 ± 20 mean ± se of failure: 440 ± 30 mean ± se of success: 270 ± 20 mean ± se of failure: 310 ± 30 mean ± sd of success: 0.34 ± 0.08 mean ± sd of failure: 0.4 ± 0.08 mean ± se of success: 0.497 ± 0.053 mean ± se of failure: 0.29 ± 0.028 mean ± sd of success: 0.31 ± 0.13 mean ± sd of failure: 0.22 ± 0.76 mean ± sd of success: 533 ± 173 mean ± sd of failure: 457 ± 131 mean ± sd of success: 371 ± 149 mean ± sd of failure: 355 ± 140 mean ± sd of success: 552.73 ± 213.69 mean ± sd of failure: 326.13 ± 99.43 mean ± sd of success: 626 ± 105 mean ± sd of failure: 608 ± 120 mean ± sd of success: 527 ± 161 mean ± sd of failure: 458 ± 188 mean ± se of success: 373 ± 45 mean ± se of failure: 263 ± 26 mean ± sd of success: 432 ± 143 mean ± sd of failure: 378 ± 134 | 0.356 <0.01 <0.05 >0.3 0.067 <0.04 <0.01
No cutpoint reported | successful extubation | Gologorskii, 1997 | 127 | sensitivity: 73 specificity: 75
Tidal Volume >325 | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Sassoon, 1993 Dojat, 1996 Yang, 1993 Yang, 1991 Mohsenifar, 1993 | 45 38 31 100 29 | sensitivity: 94 specificity: 40 sensitivity: 52.9 specificity: 76.2 sensitivity: 100 specificity: 67 sensitivity: 97 specificity: 54 sensitivity: 100 specificity: 18
Tidal Volume >360 | successful discontinuation assessment + extubation | Gandia, 1992 | 30 | sensitivity: 75 specificity: 58
Tidal Volume as ml/kg | successful discontinuation assessment successful extubation | Frutos, 1995 Ochiai, 1993 Engoren, 1999 | 73 38 82 | mean ± sd of success: 6.8 ± 1.8 mean ± sd of failure: 6.6 ± 1.9 mean ± sd of success: 9.67 ± 2.94 mean ± sd of failure: 10.08 ± 1.97 mean ± sd of success: 6.4 ± 1.9 mean ± sd of failure: 5.8 ± 1.3 | 0.7
Tidal Volume >4 ml/kg | successful discontinuation assessment + extubation successful extubation | Yang, 1991 Farias, 1998 Khan, 1996 | 100 84 213 | sensitivity: 94 specificity: 39 sensitivity: 94 specificity: 43 sensitivity: 83.6 sensitivity: 28.1
Tidal Volume >6 ml/kg | successful extubation | Khan, 1996 | 213 | sensitivity: 48.5 specificity: 71.9
Tidal Volume >6.5 ml/kg | successful discontinuation assessment + extubation | Farias, 1998 | 84 | median (IQR) of success: 6.8 (4.8, 8)
Vital Capacity | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation CVICU duration of ventilation | Hilberman, 1976 Tahvanainen, 1983 Capdevila, 1995 Vallverdu, 1998 Peters, 1979 | 124 47 67 217 49 | mean ± sd of success: 1.30 ± 0.63 mean ± sd of failure: 0.79 ± 0.30 mean ± sd of success: 0.80 ± 0.05 mean ± sd of failure: 0.76 ± 0.09 mean ± sd of success: 1.21 ± 0.68 mean ± sd of failure: 0.8 ± 0.35 mean ± sd of success: 1.63 ± 0.64 mean ± sd of failure: 1.30 ± 0.51 mean ± sd of success: 3.2 ± 1.1 mean ± sd of failure: 2.4 ± 0.9 | <0.01 0.71 0.027 <0.001 <0.01
Vital Capacity as ml/kg | successful discontinuation assessment successful extubation CVICU duration of ventilation | Hilberman, 1976 Tahvanainen, 1983 Engoren, 1999 Goodnough-Hanneman, 1994 | 124 47 82 162 | mean ± sd of success: 18.3 ± 7.2 mean ± sd of failure: 11.9 ± 4.0 mean difference P value: mean ± sd of success: 15.6 ± 6.2 mean ± sd of failure: 11.5 ± 3.9 mean ± sd of success: 14.2 ± 5 mean ± sd of failure: 11 ± 4 | <0.01 0.253 <0.05 0.001 <0.05
Tidal Volume >6 ml/kg | successful extubation | Khan, 1996 | 213 | sensitivity: 48.5 specificity: 71.9
Tidal Volume >6.5 ml/kg | successful discontinuation assessment + extubation | Farias, 1998 | 84 | median (IQR) of success: 6.8 (4.8, 8)
Vital Capacity | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation CVICU duration of ventilation | Hilberman, 1976 Tahvanainen, 1983 Capdevila, 1995 Vallverdu, 1998 Peters, 1979 | 124 47 67 217 49 | mean ± sd of success: 1.30 ± 0.63 mean ± sd of failure: 0.79 ± 0.30 mean ± sd of success: 0.80 ± 0.05 mean ± sd of failure: 0.76 ± 0.09 mean ± sd of success: 1.21 ± 0.68 mean ± sd of failure: 0.8 ± 0.35 mean ± sd of success: 1.63 ± 0.64 mean ± sd of failure: 1.30 ± 0.51 mean ± sd of success: 3.2 ± 1.1 mean ± sd of failure: 2.4 ± 0.9 | <0.01 0.71 0.027 <0.001 <0.01
Vital Capacity as ml/kg | successful discontinuation assessment successful extubation CVICU duration of ventilation | Hilberman, 1976 Tahvanainen, 1983 Engoren, 1999 Goodnough-Hanneman, 1994 | 124 47 82 162 | mean ± sd of success: 18.3 ± 7.2 mean ± sd of failure: 11.9 ± 4.0 mean difference P value: mean ± sd of success: 15.6 ± 6.2 mean ± sd of failure: 11.5 ± 3.9 mean ± sd of success: 14.2 ± 5 mean ± sd of failure: 11 ± 4 | <0.01 0.253 <0.05 0.001 <0.05
Vital Capacity % predicted preoperatively | successful discontinuation assessment CVICU duration of ventilation | Hilberman, 1976 Ingersoll, 1991 | 124 47 | mean ± sd of success: 90.7 ± 13.7 mean ± sd of failure: 71.3 ± 21.9 mean ± sd of success: 59.6 ± 15.3 mean ± sd of failure: 71.9 ± 13.9 | <0.01 <0.05
Rapid Shallow Breathing Index | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Del Rosario, 1997 Yang, 1993 Hilbert, 1998 Afessa, 1999 Gandia, 1992 Capdevila, 1995 Jubran, 1997 Vallverdu, 1998 | 49 31 40 118 30 67 31 217 | mean ± se of success: 54.5 ± 4.4 mean ± sd of success: 54.5 ±4.4 mean ± sd of success: 112.7 ±27.3 mean ± sd of success: 65.26 ±7.11 mean ± sd of success: 143.3 ±15.03 mean ± sd of success: 60 ± 2 mean ± sd of failure: 66 ± 28 mean ± sd of success: 79.2 ± 41.2 mean ± sd of failure: 103.0 ± 62.3 mean ± sd of success: 71 ± 21 mean ± sd of failure: 103 ± 15 mean ± sd of success: 50 ± 23 mean ± sd of failure: 69 ± 25 mean ± se of failure: 158 ± 20 mean ± sd of success: 65 ± 30 mean ± sd of failure: 88 ± 44 | <0.01 0.062 <0.001 0.018 <0.002 <0.001
No cutpoint reported | successful extubation | Gologorskii, 1997 | 127 | sensitivity: 84 specificity: 83
RSBI <33 | successful discontinuation assessment + extubation | Yang, 1991 | 100 | sensitivity: 75 specificity: 36
RSBI <60 | successful discontinuation assessment + extubation | Capdevila, 1995 | 67 | sensitivity: 73 specificity: 75
RSBI <65 | successful [image] mechanical support | Rivera, 1997 | 40 | sensitivity: 90 specificity: 80
RSBI <90 | successful discontinuation assessment + extubation | Gandia, 1992 | 30 | sensitivity: 83 specificity: 82
RSBI <100 | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Sassoon, 1993 Chatila, 1996a Yang, 1993 Epstein, 1995 Epstein, 1996 Leitch, 1996 Jacob, 1997 Vallverdu, 1998 | 45 100 31 94 218 163 183 217 | sensitivity: 97 specificity: 40 sensitivity: 98 specificity: 59 sensitivity: 94 specificity: 73 sensitivity: 92 specificity: 22 sensitivity: 88.6 specificity: 23.5 sensitivity: 96.3 specificity: 0 sensitivity: 97 specificity: 33 sensitivity: 90 specificity: 36
RSBI <105 | successful extubation | Lee, 1994 Mergoni, 1996 Krieger, 1997 | 52 51 49 | sensitivity: 72 specificity: 11 sensitivity: 65 specificity: 58 sensitivity: 74 specificity: 73
RSBI <130 | successful extubation successful discontinuation assessment + extubation | Krieger, 1997 Yang, 1991 Mohsenifar, 1993 | 49 100 29 | sensitivity: 92 specificity: 57 sensitivity: 97 specificity: 64 sensitivity: 100 specificity: 27
RSBI standardized to body weight | successful discontinuation assessment + extubation | Farias, 1998 | 84 | median (IQR) of success: 6.5 (4.3, 8.7) median (IQR) of failure: 10.5 (8.2, 14.3)
RSBI in ml/kg < 4 ml/kg | successful extubation | Khan, 1996 | 213 | sensitivity: 24.1 specificity: 76.5 beta P value: 0.34
RSBI in ml/kg < 8 ml/kg | successful extubation | Khan, 1996 | 213 | sensitivity: 63.8 specificity: 55.9 beta P value: 0.34
RSBI in ml/kg < 11 ml/kg | successful extubation successful discontinuation assessment + extubation | Baumeister, 1997 Farias, 1998 | 47 84 | sensitivity: 78.9 specificity: 77.9 sensitivity: 86 specificity: 48
RSBI occlusion pressure index | successful discontinuation assessment + extubation | Vallverdu, 1998 | 217 | mean ± sd of success: 241 ± 177 mean ± sd of failure: 452 ± 363 | <0.001
RSBI occlusion pressure index <450 | successful discontinuation assessment | Sassoon, 1993 | 45 | sensitivity: 97 specificity: 60
Occlusion Pressure at 0.1 sec (P_0.1_) | successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Del Rosario, 1997 Hilbert, 1998 Capdevila, 1995 Vallverdu, 1998 | 49 40 67 217 | mean ± se of success: 3.2 ± 0.2 mean ± se of failure: 5.2 ± 1.3 mean ± sd of success: 2.4 ± 0.9 mean ± sd of failure: 2.9 ± 0.7 mean ± sd of success: 3.62 ± 1.35 mean ± sd of failure: 7.38 ± 2.67 mean ± sd of success: 3.6 ± 1.5 mean ± sd of failure: 5.0 ± 2.4 | 0.001 <0.001
P_0.1_< 3.4 | successful discontinuation assessment + extubation | Gandia, 1992 | 30 | sensitivity: 75 specificity: 61
P_0.1_ <4.4 | successful discontinuation assessment + extubation | Saito, 1991 | 23 | sensitivity: 100 specificity: 55.6
P_0.1_ <4.5 | successful [image] mechanical support successful discontinuation assessment + extubation | Rivera, 1997 Vallverdu, 1998 | 40 217 | sensitivity: 100 specificity: 100 sensitivity: 75 specificity: 55
P_0.1_ <5.0 | successful discontinuation assessment + extubation | Capdevila, 1995 | 67 | sensitivity: 87 specificity: 91
P_0.1_ <5.5 | successful discontinuation assessment | Sassoon, 1993 | 45 | sensitivity: 97 specificity: 40
P_0.1_/MIP | successful discontinuation assessment + extubation | Capdevila, 1995 Vallverdu, 1998 | 67 217 | mean ± sd of success: 0.05 ± 0.01 mean ± sd of failure: 0.14 ± 0.04 mean ± sd of success: 0.063± 0.032 mean ± sd of failure: 0.103± 0.056 | 0.001 <0.001
P_0.1_/MIP <0.09 | successful discontinuation assessment + extubation | Capdevila, 1995 | 67 | sensitivity: 98 specificity: 100
P_0.1_/MIP <0.14 | successful extubation successful discontinuation assessment + extubation | Mergoni, 1996 Gandia, 1992 | 51 30 | sensitivity: 85 specificity: 36 sensitivity: 1 specificity: 82
Maximum Exspiratory Pressure | successful discontinuation assessment + extubation CVICU duration of ventilation | Vallverdu, 1998 Peters, 1979 | 217 49 | mean ± sd of success: 53 ± 25 mean ± sd of failure: 37± 17 mean ± sd of success: 68 ± 24 mean ± sd of failure: 47 ± 26 | <0.001 <0.04
Pressure Time Product | successful discontinuation assessment + extubation | Jubran, 1997 | 31 | mean ± se of success: 158 ± 23 mean ± se of failure: 255 ± 59 | 0.17
Pressure Time Product <275 | successful [image] mechanical support | Rivera, 1997 | 40 | sensitivity: 100 specificity: 80
Peak Inspiratory Pressure | successful extubation | Krieger, 1997 | 49 | mean ± sd of success: 25 ±8 mean ± sd of failure: 29±7.5
Peak Inspiratory Pressure <25 | successful extubation | Khan, 1996 | 213 | sensitivity: 44.3 specificity: 82.4 beta P value: 0.001
Peak Inspiratory Pressure <30 | successful extubation | Khan, 1996 | | sensitivity: 77 specificity: 47.1 beta P value: 0.001
Intrinsic PEEP | successful [image] mechanical support successful discontinuation assessment successful extubation successful discontinuation assessment + extubation | Rivera, 1997 Del Rosario, 1997 Krieger, 1997 Afessa, 1999 Jubran, 1997 | 40 49 49 118 31 | mean ± sd of success: 1.6 ± 0.8 mean ± sd of failure: 5.8 ± 2.4 mean ± se of success: 2 ± 0.4 mean ± se of failure: 2 ± 0.5 mean ± sd of success: 0.53 ± 1.3 mean ± sd of failure: 1.5 ± 2.8 mean ± sd of success: 1.0± 2.3 mean ± sd of failure: 1.5 ± 2.5 mean ± se of success: 0.7 ± 0.1 mean ± se of failure: 2 ± 0.5 | <0.001 0.395 <0.03
FiO_2_ | successful extubation successful discontinuation assessment + extubation CVICU duration of ventilation | Krieger, 1997 Engoren, 1999 Mohsenifar, 1993 Goodnough-Hanneman, 1994 | 49 82 29 162 | mean ± sd of success: 0.4 ± 0.06 mean ± sd of failure: 0.38 ± 0.06 mean ± sd of success: 0.53 ± 0.08 mean ± sd of failure: 0.61 ± 0.19 mean ± sd of success: 35 ± 8 mean ± sd of failure: 40 ± 7 mean ± sd of success: 0.61 ± 0.09 mean ± sd of failure: 0.72 ± 0.17 | <0.05 >0.3 <0.001
Gastric Intramucosal pH | successful discontinuation assessment + extubation | Mohsenifar, 1993 | 29 | mean ± sd of success: 7.45 ± 0.13 mean ± sd of failure: 7.36 ± 0.2 | 0.07
Gastric Intramucosal pH >7.3 | successful discontinuation assessment + extubation | Bouachour, 1996 | 26 | sensitivity: 100 specificity: 100
Gastric Intramucosal pH Change | successful discontinuation assessment + extubation | Mohsenifar, 1993 | 29 | mean of success: 0.01 mean of failure: 0.27
Gastric Intramucosal PCO_2_ | successful discontinuation assessment + extubation | Mohsenifar, 1993 | 29 | mean ± sd of success: 37 ± 12 mean ± sd of failure: 49 ± 23 | 0.07
Gastric Intramucosal PCO_2_ <60 | successful discontinuation assessment + extubation | Bouachour, 1996 | 26 | sensitivity: 95 specificity: 100
Gastric Intramucosal PCO_2_ Change | successful discontinuation assessment + extubation | Mohsenifar, 1993 | 29 | mean of success: 1 mean of failure: 62 | <0.01
Cuff Leak Test | successful extubation | Fisher, 1992 | 72 | sensitivity: 88.7 specificity: 100
Patient-Ventilator Asynchrony | successful discontinuation assessment | Chao, 1997 | 174 | sensitivity: 96.7 specificity: 19.3
Daily Screening Test | successful extubation | Ely, 1996 | 300 | sensitivity: 88 specificity: 67
Successful 2-hour T-piece Trial | successful discontinuation assessment | Dojat, 1996 | 38 | sensitivity: 100 specificity: 76
Cardiac Index Before Bypass | successful discontinuation assessment | Hilberman, 1976 | 124 | mean ± sd of success: 2.6 ± 0.8 mean ± sd of failure: 2.1 ± 0.6
Total Bypass Time | successful extubation | Rady, 1999 | 11330 | mean ± sd of success: 108 ±46 mean ± sd of failure: 136 ± 75 | <0.0001
Total Operating Room Time | successful extubation | Rady, 1999 | 11330 | mean ± sd of success: 5.2 ± 1.5 mean ± sd of failure: 6.5 ± 3.1 | <0.0001
Weaning Predictors Specific to CVICU Surgery type:CABG vs other | CVICU duration of ventilation | Peters, 1979 Doering, 1997 | 49 62 | sensitivity: 71.4 specificity: 71.4 sensitivity: 90.9 specificity: 25.5
Total OR time | CVICU duration of ventilation | London, 1998 | 299 | mean ± sd of success: 4.9 ± 1 mean ± sd of failure: 5.4 ± 1.3 | 0.001
Fentanyl dose | CVICU duration of ventilation | London, 1998 | 299 | mean ± sd of success: 35.6 ± 12.4 mean ± sd of failure: 45.5 ± 22 | 0.002
Midazolam dose | CVICU duration of ventilation | London, 1998 | 299 | mean ± sd of success: 0.07 ± 0.04 mean ± sd of failure: 0.09 ± 0.06 | 0.003
Mean Arterial Blood pressure | CVICU duration of ventilation | Goodnough-Hanneman, 1994 | 162 | mean ± sd of success: 93 ± 16 mean ± sd of failure: 79 ± 17 | <0.001
Age | CVICU duration of ventilation | Goodnough-Hanneman, 1994 | 162 | mean ± sd of success: 61 ± 12 mean ± sd of failure: 66 ± 9
Study Derived Predictive Index | CVICU duration of ventilaiton | Kanter, 1986 | 140 | sensitivity: 57 specificity: 94.7
Table N2: Observational Study Results: Important Weaning Predictors Determined by Regression Analysis Only
Observational Study Results: Important Weaning Predictors Determined by Regression Analysis Only
Predictor | Outcome | Author, Year | Number of Patients | Beta P Value
Prior Myocardial Infarction | CVICU duration of ventilation | Bando, 1997 | 586 | 0.039
CHF/Pulmonary Edema | CVICU duration of ventilation | Bando, 1997 | 586 | <0.001
Coma | CVICU duration of ventilation | Bando, 1997 | 586 | <0.001
Vital Capacity | CVICU duration of ventilation | Bando, 1997 | 586 | 0.359
% Predicted VC | CVICU duration of ventilation | Bando, 1997 | 586 | 0.406
% Predicted FeV_1_ | CVICU duration of ventilation | Bando, 1997 | 586 | 0.401
Second Surgical Procedure | CVICU duration of ventilation | Kanter, 1986 | 140 | <0.005
Prior Cardiac Surgery | CVICU duration of ventilation | Bando, 1997 | 586 | <0.001
Priority Operation | CVICU duration of ventilation | Bando, 1997 | 586 | 0.005
Cardiomegaly (on CXR) | CVICU duration of ventilation | Bando, 1997 | 586 | 0.002
Preoperative Mechanical Ventilation | CVICU duration of ventilation | Kanter, 1986 | 140 | <0.05
Failed Extubation | CVICU duration of ventilation | Kanter, 1986 | 140 | <0.005
New Q-Waves | CVICU duration of ventilation | Bando, 1997 | 586 | <0.001
Decreased Cardiac Output | CVICU duration of ventilation | Bando, 1997 | 586 | <0.001
Age | CVICU duration of ventilation | Kanter, 1986 | 140 | <0.005
Tidal Volume | successful extubation | Khan, 1996 | 213 | 0.01
FiO_2_ | successful extubation | Khan, 1996 | 213 | 0.018
Oxygenation Index | successful extubation | Khan, 1996 | 213 | 0.012
Observation Study Results: Important Weaning Predictors Studied in 50 Patients or Fewer
Predictor | Outcome | Author, Year | Number of Patients | Predictive Power | Reported P Value
VE/V_t_ | successful discontinuation assessment | Jabour, 1991 | 38 | mean ± sd of success: 25 ± 11 mean ± sd of failure: 42 ± 16 | <0.001
Tidal Volume Expressed in ml/kg | successful discontinuation assessment | Jabour, 1991 | 38 | mean ± sd of success: 5.9 ± 1.7 mean ± sd of failure: 4.8 ± 1.7 | <0.05
RSBI <100 AND NIP/PI_max_<0.03 | successful extubation | Yang, 1993 | 31 | sensitivity: 81 specificity: 93
Maximum Expiratory Pressure | CVICU duration of ventilation | Peters, 1979 | 49 | mean ± sd of success: 68 ± 24 mean ± sd of failure: 47 ± 26 | <0.04
PI_max_ | successful discontinuation assessment | Jabour, 1991 | 38 | mean ± sd of success: 49 ± 11 mean ± sd of failure: 35 ± 15 | <0.005
Pbreath/NIP | successful discontinuation assessment | Jabour, 1991 | 38 | mean ± sd of success: 0.31 ± 0.1 mean ± sd of failure: 0.39 ± 0.14 | <0.05
Change in P_t_/NIF <0.4 | successful extubation | Kline, 1987 | 50 | sensitivity: 93.1 specificity: 100
Pressure Time Index | successful discontinuation assessment | Jabour, 1991 | 38 | mean ± sd of success: 0.12 ± 0.03 mean ± sd of failure: 0.17 ± 0.07 | <0.02
Inspiratory Effort Quotient <0.19 | successful discontinuation assessment + extubation | Gandia, 1992 | 30 | sensitivity: 100 specificity: 82
Effective Inspiratory Impedance | successful extubation | Hilbert, 1998 | 40 | mean ± sd of success: 5.2 ± 1.2 mean ± sd of failure: 6.1 ± 1.3
CROP Index in ml/kg <0.1 | successful extubation | Baumeister, 1997 | 47 | sensitivity: 100 specificity: 100
MMEF 50-75 | CVICU duration of ventilation | Peters, 1979 | 49 | mean ± sd of success: 1.8 ± 1 mean ± sd of failure: 1.1 ± 0.6 | <0.01
MMEF 75-85 | CVICU duration of ventilation | Peters, 1979 | 49 | mean ± sd of success: 0.9 ± 0.5 mean ± sd of failure: 0.5 ± 0.2 | <0.003
Expiratory Time | successful discontinuation assessment + extubation | Jubran, 1997 | 31 | mean ± se of success: 1.68 ± 0.16 mean ± se of failure: 1.29 ± 0.18
Change in Intrapleural Pressure | successful extubation | Kline, 1987 | 50 | mean ± sd of success: 11.2 ± 2.9 mean ± sd of failure: 15.2 ± 4.5
Change in Intrapleural Pressure/NIF | successful extubation | Kline, 1987 | 50 | mean ± sd of success: 0.32 ± 0.07 mean ± sd of failure: 0.53 ± 0.1
Effective Inspiratory Impedance <10 | successful discontinuation assessment | Sassoon, 1993 | 45 | sensitivity: 89 specificity: 40
Leak Test in Neonates | successful extubation | Adderley, 1987 | 28 | sensitivity: 75 specificity: 62.5
Statistical Prediction Model | successful discontinuation assessment + extubation | Ashutosh, 1992 | 30 | sensitivity: 93.3 specificity: 93.3
Neural Network Analysis | successful discontinuation assessment + extubation | Ashutosh, 1992 | 30 | sensitivity: 100 specificity: 93.3
Knowledge-Based System | successful discontinuation assessment | Dojat, 1996 | 38 | sensitivity: 100 specificity: 90.5
Weaning Index (PTI x VE/V_t_) | successful discontinuation assessment | Jabour, 1991 | 38 | sensitivity: 95 specificity: 96
Right Atrial Pressure | successful discontinuation assessment | Delooz, 1976 | 41 | mean ± sd of success: 5.2 ± 4.2 mean ± sd of failure: 11 ± 6.2
Pre-Operative Length of Stay (days) | CVICU duration of ventilation | Ingersoll, 1991 | 47 | mean ± sd of success: 6.3 ± 6.7 mean ± sd of failure: 12.2 ± 10.8
Age | successful discontinuation assessment | Del Rosario, 1997 | 49 | mean ± sd of success: 63.1 ± 10 mean ± sd of failure: 72 ± 7 | <0.05

Evidence Table 15. Pooled results of observational studies of weaning predictors

Predicting Successful Stepwise Reductions in Mechanical Support
Predictor | Author (threshold) | Study LR + (95% CI) | Summary LR + (95% CI) | Summary LR -(95% CI) | Summary OR (95% CI) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
Respiratory Rate continuous data | Stroetz (38 breaths/ min) Rivera (38 breaths/min) | 1.14 (0.87, 1.50) 1.08 (0.90, 1.29) | 1.10 (0.95, 1.28) | 0.32 (0.06,1.71) | 3.57 (0.57,22.47) | 0.97 (0.92, 1.02) | 0.13 (0.04, 0.22)
Predicting Successful Discontinuation Assessment
Predictor | Author (threshold) | Study LR + (95% CI) | Summary LR + (95% CI) | Summary LR -(95% CI) | Summary OR (95% CI) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
Minute Ventilation binary data continuous data | Sassoon (12 L/min) Chatila (10 L/min) Del Rosario (12 L/min) | 0.81 (0.40, 1.64) 1.18 ( 0.90,1.52) 1.12 (0.49, 2.55) | 1.13 (0.88,1.43) 1.12 (0.49, 2.55) | 0.88 (0.48,1.61) 0.93 (0.56,1.55) | 1.27 (0.49, 3.27) 1.21 (0.32, 4.57) | 0.60 (0.22, 0.98) 0.42 (0.28, 0.55) | 0.41 (0.24, 0.57) 0.63 (0.50, 0.76)
Respiratory Rate binary data continuous data | Dojat (30 breaths/min) Sassoon (38 breaths/min) Del Rosario (38 breaths/min) Jabour (38 breaths/min) Frutos (38 breaths/min) Jabour (38 breaths/min) | 3.89 (1.88, 8.05) 1.41 (0.93, 2.12) 1.63 (1.01, 2.62) 1.08 (0.87, 1.35) 1.12 (0.90, 1.40) 1.05 (0.86, 1.27) | 2.23 (0.83, 6.03) 1.11 (0.98, 1.24) | 0.09 (0.02,0.40) 0.23 (0.08,0.63) | 25.89 (2.94,228.18) 5.37 (1.72,16.79) | 0.97 (0.93, 1.00) 0.97 (0.95, 1.00) | 0.53 (0.11, 0.96) 018 (0.06, 0.30)
Tidal Volume binary data continuous data | Dojat (325 ml) Sassoon (325 ml) Del Rosario (325 ml) Saura (325 ml) | 2.11 (0.91, 4.92) 1.57 (0.96, 2.60) 1.27 (0.85, 1.89) 1.02 (0.75, 1.37) | 1.70 (1.10, 2.61) 1.10 (0.87, 1.40) | 0.38 (0.11,1.34) 0.49 (0.17,1.37) | 4.87 (1.68,14.11) 2.33 (0.63, 8.58) | 0.74 (0.34, 1.13) 0.88 (0.81, 0.95) | 0.58 (0.25, 0.91) 0.22 (0.04, 0.40)
Rapid Shallow Breathing Index binary data | Dojat (100 breaths/min/L) Sassoon (100 breaths/min/L) Chatila (100 breaths/min/L) | 1.22 ( 0.93,1.61) 1.62 (0.99, 2.66) 2.39 (1.63, 3.52) | 1.66 (1.08, 2.55) | 0.11 (0.03,0.37) | 15.86 (3.09,81.53) | 0.97 (0.94, 0.99) | 0.42 (0.21, 0.63)
Negative Inspiratory Force binary data continuous data | Dojat (25cm H_2_0) Chatila (30cm H_2_0) Frutos (25cm H_2_0) Hilberman (25cm H_2_0) | 1.22 (0.93, 1.41) 2.19 (1.31, 3.67) 1.21 (0.75, 1.97) 1.57 (1.04, 2.36) | 1.57 (0.89, 2.77) 1.41 (1.03, 1.92) | 0.47 (0.32,0.70) 0.53 (0.35,0.81) | 4.39 (2.00, 9.67) 2.71 (1.31, 5.61) | 0.79 (0.54, 1.04) 0.74 (0.68, 0.80) | 0.48 (0.04, 0.91) 0.46 (0.31, 0.60)
PI_max_ binary data continuous data | Sassoon (20 cm H_2_O) Del Rosario (20 cm H_2_O) Jabour (20 cm H_2_O) | 1.32 (0.87, 2.01) 1.09 (0.79, 1.49) 1.18 (0.97, 1.42) | 1.15 (0.98, 1.35) | 0.50 (0.15,1.66) | 2.41 (0.58,10.00) | 0.92 (0.81, 1.04) | 0.19 (0.11, 0.27)
Predicting Successful Extubation
Predictor | Author (threshold) | Study LR + (95% CI) | Summary LR + (95% CI) | Summary LR -(95% CI) | Summary OR (95% CI) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
Minute Ventilation binary data continuous data | Gologorskii (not specified) Mergoni (10 L/min) Yang (15 L/min) Leitch (10 L/min) Kreiger (12 L/min) Tahvanainen (12 L/min) Engoren (12 L/min) Afessa (12 L/min) | 1.91 (1.23, 2.98) 1.25 (0.82, 1.91) 1.02 (0.71, 1.45) 1.33 (0.37, 4.77) 1.02 (0.89, 1.16) 1.00 (0.85, 1.17) 1.04 (0.94, 1.16) 0.90 (0.70, 1.15) | 1.31 (0.96, 1.79) 1.01 (0.94, 1.09) | 0.63 (0.48,0.83) 1.16 (0.70,1.90) | 2.30 (1.35, 3.93) 0.85 (0.43, 1.69) | 0.63 (0.51, 0.74) 0.89 (0.78, 1.00) | 0.52 (0.36, 0.67) 0.11 (0.02, 0.20)
Respiratory Rate binary data continuous data | Gologorskii (not specified) Mergoni (30 breaths/min) DeHaven (30 breaths/ min) Yang (38 breaths/min) Kreiger (38 breaths/min) Kline (38 breaths/min) Ochiai (38 breaths/min) Tahvanainen (38 breaths/min) Hibert (38 breaths/min) Engoren (38 breaths/min) | 2.54 (1.52, 4.24) 2.01 (1.25, 3.25) 1.00 (0.87, 1.15) 1.61 (0.97, 2.65) 1.04 (0.89, 1.21) 1.01 (0.93, 1.09) 1.00 (0.91, 1.10) 1.01 (0.87, 1.19) 1.02 (0.91, 1.15) 1.08 (0.94, 1.24) | 1.64 (1.00, 2.68) 1.02 (0.97, 1.07) | 0.52 (0.34,0.79) 0.58 (0.26,1.32) | 3.23 (1.24, 8.39) 1.82 (0.73, 4.51) | 0.77 (0.69, 0.85) 0.97 (0.95, 0.99) | 0.51 (0.17, 0.84) 0.06 (0.02, 0.10)
Tidal Volume binary data continuous data | Gologorskii (not specified) Yang (325 ml) Kreiger (325 ml) Kline (325 ml) Tahvanainen (325 ml) Engoren (325 ml) | 2.92 (1.70, 5.01) 2.82 (1.43, 5.58) 3.83 (0.80,18.39) 0.71 (0.49, 1.02) 0.75 (0.33, 1.73) 1.05 (0.88, 1.25) | 2.88 (1.89, 4.40) 0.93 (0.64, 1.35) | 0.20 (0.03,1.26) 0.98 (0.56,1.73) | 13.37(2.38,75.13) 1.44 (0.47, 4.40) | 0.85 (0.62, 1.09) 0.56 (0.29, 0.84) | 0.73(0.66, 0.80) 0.45 (0.08, 0.82)
Rapid Shallow Breathing Index binary data continuous data | Gologorskii (not specified) Lee (100 breaths/min/L) Mergoni (105breaths/min/L) Leitch (105 breaths/min/L) Epstein (100 breaths/min/L) Epstien (100 breaths/min/L) Yang (100breaths/min/L) Krieger (100breaths/min/L) Hilbert (100 breaths/min/L) Afessa (100 breaths/min/L) | 4.67 (2.42, 8.99) 0.84 (0.61, 1.16) 1.52 (0.99, 2.36) 1.10 (0.76, 1.59) 1.17 (0.96, 1.42) 1.20 (0.93, 1.56) 3.24 (1.46, 7.19) 2.51 (1.02, 6.18) 1.14 (0.92, 1.42) 1.43 (1.05, 1.96) | 1.49 (1.11, 1.99) 1.24 (1.00, 1.54) | 0.39 (0.25,0.62) 0.58 (0.37,0.90) | 4.44 (1.85,10.64) 2.57 (1.24, 5.32) | 0.84 (0.77, 0.90) 0.84 (0.55, 1.12) | 0.44 (0.24, 0.65) 0.33 (0.04,0.70)
Rapid Shallow Breathing Index Standardized to Weight binary data | Khan (8) Baumeister (11) | 1.44 (0.98, 2.12) 3.13 (1.06, 9.27) | 1.79 (0.98, 1.40) | 0.46 (0.21,1.01) | 4.11 (0.90,18.69) | 0.70 (0.56, 0.84) | 0.65 (0.46, 0.84)
Negative Inspiratory Force continuous data | Yang (25 cm H_2_O) Engoren (25 cm H_2_O) | 0.23 (0.01, 4.06) 1.09 (0.97, 1.22) | 1.00 ( 0.51,1.98) | 0.78 (0.22,2.67) | 1.14 (0.06,20.55) | 0.50 (0.42,1.42) | 0.48 (-0.26,1.22)
PI_max_ binary data continuous data | Yang (15 cm H_2_O) Leitch (20 cm H_2_O) Mergoni (30 cm H_2_O) Kreiger (20 cm H_2_O) Kline (20 cm H_2_O) Tahvanainen (20 cm H_2_O) Afessa (20 cm H_2_O) | 1.15 (0.92, 1.44) 1.29 (0.58, 2.87) 1.20 (0.87, 1.66) 1.10 (0.89, 1.37) 1.08 (0.89, 1.30) 0.98 (0.83, 1.16) 1.03 (0.94, 1.13) | 1.17 (0.98, 1.40) 1.03 (0.96, 1.11) | 0.60 (0.33,1.11) 0.56 (0.22,1.42) | 4.53 (1.42,14.39) 1.85 (0.68, 5.05) | 0.90 (0.79, 1.01) 0.95 (0.92, 0.98) | 0.27 (0.14, 0.40) 0.08 (0.05, 0.12)
P_0.1_/MIP binary data | el-Khatib(0.30) Yang(0.30) | 2.70 (0.57,12.83) 2.14 (1.03, 4.46) | 2.23 (1.15, 4.34) | 0.63 (0.36,1.10) | 4.53 (1.42,14.39) | 0.53 (0.14, 0.92) | 0.78 (0.56, 0.99)
CROP Index | Baumeister Khan | 19.74 (1.32,294.3) 1.05 (0.74, 1.49) | 3.31 (0.20,54.80) | 0.14 (0.00,8.87) | 30.6 (0.03,34057) | 0.77 (0.35, 1.19) | 0.71 (0.24, 1.18)
Predicting Successful Discontinuation Assessment + Extubation
Predictor | Author (threshold) | Study LR + (95% CI) | Summary LR + (95% CI) | Summary LR -(95% CI) | Summary OR (95% CI) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
Minute Ventilation binary data continuous data | Sahn (10 L/min) Yang (15 L/min) Gandia (12.5 L/min) Jacob (10 L/min) Jubran (12 L/min) Capdevila (12 L/min) Vallverdu (12 L/min) Kreiger (12 L/min) Ashutosh (12 L/min) | 1.82 (1.17,2.82) 0.95 (0.74,1.22) 2.37 (0.93,6.05) 1.28 (0.85,1.94) 1.31 (0.92,1.85) 0.95 (0.49,1.85) 0.72 (0.59,0.89) 1.04 (0.90,1.20) 0.79 (0.46,1.36) | 1.36 (0.93,1.98) 0.94 (0.75,1.19) | 0.45 (0.20,1.01) 1.18 (0.74,1.86) | 3.43 (0.93,12.60) 0.83 (0.39, 1.75) | 0.79 (0.65, 0.93) 0.67 (0.46, 0.89) | 0.44 (0.26, 0.63) 0.30 (0.16, 0.43)
Respiratory Rate binary data continuous data | Ashutosh (38 breaths/min) Yang (38 breaths/min) Mohsenifar (38 breaths/min) Gandia (35 breaths/min) Jubran (38 breaths/min) Capdevila (38 breaths/min) Vallverdu (38 breaths/min) Kreiger (38 breaths/min) | 1.63 (1.08,2.47) 1.42 (1.06,1.90) 1.37 (0.95,1.99) 3.01 (1.21,7.50) 1.55 (1.06,2.25) 1.01 (0.89,1.15) 1.14 (1.05,1.24) 1.04 (0.96,1.13) | 1.50 (1.23,1.38) 1.09 (1.00,1.19) | 0.23 (0.12,0.44) 0.14 (0.05,0.42) | 8.82 (3.54,21.98) 8.14 (2.66,24.92) | 0.93 (0.87, 0.99) 0.99 (0.98, 1.00) | 0.45 (0.25, 0.65) 0.11 (0.04, 0.18)
Tidal Volume binary data continuous data | Ashutosh (325 ml) Yang (325 ml) Mohsenifar (325 ml) Gandia (408ml) Jubran (325 ml) Capdevila (325 ml) Vallverdu (325 ml) Kreiger (325 ml) | 1.67 (0.93,2.98) 2.06 (1.39,3.06) 1.23 (0.91,1.66) 1.75 (0.90,3.43) 2.06 (0.90,4.70) 1.20 (0.86,1.68) 1.18 (0.99,1.41) 1.07 (0.77,1.47) | 1.58 (1.20,2.08) 1.18 (1.03,1.36) | 0.29 (0.14,0.63) 0.70 (0.53,0.93) | 6.76 (2.67,17.11) 1.74 (1.13, 2.68) | 0.89 (0.80, 0.98) 0.73 (0.60, 0.86) | 0.46 (0.29, 0.63) 0.42 (0.30, 0.54)
Rapid Shallow Breathing Index binary data continuous data | Gandia (105 breaths/min/L) Jacob (100 breaths/min/L) Vallverdu (100breaths/min/L) Yang (105 breaths/min/L) Mohsenifar (105breaths/min/L) Capdevila (60breaths/min/L) Jubran (100breaths/min/L) | 1.52 (0.94,2.47) 1.47 (1.03,2.10) 1.41 (1.20,1.66) 2.65 (1.63,4.32) 1.37 (0.95,1.99) 2.69 (1.08,6.67) 2.79 (1.19,6.55) | 1.58 (1.30,1.90) 2.79 (1.19,6.55) | 0.22 (0.13,0.37) 0.39 (0.17,0.89) | 8.45(4.59, 15.54) 7.25 (1.55,33.83) | 0.92 (0.87, 0.97) 0.71 (0.56, 0.87) | 0.47 (0.33, 0.60) 0.74 (0.60, 0.89)
Negative Inspiratory Force binary data | Jacob (not specified) Ashutosh (25 cm H_2_O) Sahn (25 cm H_2_O) Mohsenifar (20 cm H_2_O) | 1.05 (0.90,1.24) 2.45 (1.21,4.99) 35.79 (2.33,550) 1.11 (0.89,1.40) | 1.32 (0.92,1.90) | 0.14 (0.03,0.68) | 18.69 (1.49,234.4) | 0.97 (0.93, 1.00) | 0.46 (-0.11,1.03)
PI_max_ binary data continuous data | Jubran (not specified) Gandia (not specified) Yang (15 cm H_2_O) Capdevila (50 cm H_2_O) Vallverdu (20 cm H_2_O) Kreiger (20 cm H_2_O) | 1.12 (0.91,1.38) 3.01 (1.21,7.50) 1.12 (0.98,1.29) 1.38 (0.85,2.24) 1.01 (0.97,1.06) 1.13 (0.94,1.37) | 1.19 (0.99, 1.43) 1.03 (0.95, 1.11) | 0.34 (0.19,0.59) 0.51 (0.25,1.06) | 5.33 (2.18,13.03) 2.10 (0.89, 4.96) | 0.90 (0.81, 0.99) 0.94 (0.86, 1.02) | 0.35 (0.09, 0.61) 0.12 (-0.06,0.29)
P_0.1_/MIP binary data | Gandia (0.09) Capdevila (0.09) | 10.31 (0.66,162) 25.30 (1.67,383) | 16.25 (2.35,112.5) | 0.15 (0.01,3.08) | 114 (2.24, 5814) | 0.69 (0.12, 1.25) | 0.96 (0.93, 1.00)
Predicting Successful Stepwise Reduction in Mechanical Support and Discontinuation Assessment
Predictor | Author (threshold) | Study LR + (95% CI) | Summary LR + (95% CI) | Summary LR -(95% CI) | Summary OR (95% CI) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
Minute Ventilation continuous data | Amoateng (12 L/min) septic patients Amoateng (12 L/min) nonseptic patients | 0.97 (0.54,1.75) 1.11 (0.76,1.61) | 1.07 (0.78, 1.46) | 0.92 (0.32,2.69) | 1.16 (0.27, 5.05) | 0.78 (0.59, 0.97) | 0.26 (0.14, 0.37)
Rapid Shallow Breathing Index continuous data | Amoateng (100 breaths/min/L) septic patients Amoateng (100 breaths/min/L) nonseptic patients | 1.88 (1.10,3.21) 1.39 (0.96,2.01) | 1.53 (1.13, 2.08) | 0.22 (0.04,1.15) | 7.73 (1.13,52.96) | 0.91 (0.84, 0.99) | 0.43 (0.23, 0.62)
Negative Inspiratory Force continuous data | Amoateng (25 cm H_2_O) septic patients Amoateng (25 cm H_2_O) non-septic patients | 1.14 (0.51,2.54) 1.42 (0.89,2.25) | 1.34 (0.90, 2.00) | 0.73 (0.32,1.69) | 1.95 (0.49, 7.80) | 0.71 (0.42, 1.01) | 0.45 (0.32, 0.58)
Predicting the Duration of Ventilation in Cardiac Surgery Patients
Predictor | Author (threshold) | Study LR + (95% CI) | Summary LR + (95% CI) | Summary LR -(95% CI) | Summary OR (95% CI) | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
CABG binary data | Doering Peters | 1.18 (0.90,1.54) 2.36 (1.06,5.26) | 1.50 (0.79, 2.86) | 0.42 (0.24,0.75) | 4.25 (1.46,12.35) | 0.80 (0.64, 0.96) | 0.48 (0.05, 0.91)