# References

Abalos A, Leibowitz AB, Distefano D, et al. Myocardial ischemia during the weaning period. Am J Crit Care. 1992;1(3):32-6. [pmid: 1307904].
Adderley RJ, Mullins GC. When to extubate the croup patient: The "leak" test. Can J Anaeth. 1987;34(3(Pt 1):304-6.
Afessa B, Hogans L, Murphy R. Predicting 3-day and 7-day outcomes of weaning from mechanical ventilation. Chest. 1999;116:456-61. [pmid: 10453876].
al-Saady NM, Blackmore CM, Bennett ED. High fat, low carbohydrate, enteral feeding lowers PaCO2 and reduces the period of ventilation in artificially ventilated patients. Intensiv Care Med. 1989;15(5):290-5.
Amoateng-Adjepong Y, Jacob BK, Ahmad M, et al. The effect of sepsis on breathing pattern and weaning outcomes in patients recovering from respiratory failure. Chest. 1997;112(2):472-7. [pmid: 9266886].
Anene O, Meert KL, Uy H, et al. Dexamethasone for the prevention of postextubation airway obstruction: A prospective, randomized, double-blind, placebo-controlled trial. Crit Care Med. 1996;24(10):1666-9. [pmid: 8874303].
Arom KV, Emery RW, Petersen RJ, et al. Cost-effectiveness and predictors of early extubation. Ann Thorac Surg. 1995;60(1):127-32. [pmid: 7598574].
Ashutosh K, Lee H, Mohan CK, et al. Prediction criteria for successful weaning from respiratory support: Statistical and connectionist analyses [published erratum appears in Crit Care Med 1994 Jan;22(1):183]. Crit Care Med. 1992;20(9):1295-301. [pmid: 1521445].
Bailey CR, Jones RM, Kelleher AA. The role of continuous positive airway pressure during weaning from mechanical ventilation in cardiac surgical patients. Anaesthesia. 1995;50(8):677-81. [pmid: 7645695].
Bando K, Sun K, Binford RS, et al. Determinants of longer duration of endotracheal intubation after adult cardiac operations. Ann Thorac Surg. 1997;63(4):1026-33. [pmid: 9124900].
Bassili H, Dietel M. Effect of nutritional support on weaning patients off mechanical ventilators. J Parental Enteral Nutr. 1981;5:161-3.
Baumeister BL, el-Khatib M, Smith PG, et al. Evaluation of predictors of weaning from mechanical ventilation in pediatric patients. Pediatr Pulmonol. 1997;24(5):344-52. [pmid: 9407568].
Berry PD, Thomas SD, Mahon SP, et al. Myocardial ischaemia after coronary artery bypass grafting: early vs late extubation. Br J Anaesth. 1998;80(1):20-5. [pmid: 9505772].
Bouachour G, Guiraud MP, Gouello JP, et al. Gastric intramucosal pH: An indicator of weaning outcome from mechanical ventilation in COPD patients. Eur Respir J. 1996;9(9):1868-73. [pmid: 8880104].
Bouley GH, Froman R, Shah H. The experience of dyspnea during weaning. Heart Lung. 1992;21(5):471-6. [pmid: 1399666].
Brochard L, Rauss A, Benito S, et al. Comparison of three methods of gradual withdrawal from ventilatory support during weaning from mechanical ventilation. Am J Respir Crit Care Med. 1994;150(4):896-903. [pmid: 7921460].
Burns SM, Marshall M, Burns JE, et al. Design, testing, and results of an outcomes-managed approach to patients requiring prolonged mechanical ventilation. Am J Crit Care. 1998;7(1):45-57. [pmid: 9429683].
Capdevila XJ, Perrigault PF, Perey PJ, et al. Occlusion pressure and its ratio to maximum inspiratory pressure are useful predictors for successful extubation following T-piece weaning trial. Chest. 1995;108(2):482-9. [pmid: 7634888].
Chaney MA, Nikolov MP, Blakeman B, et al. Pulmonary effects of methylprednisolone in patients undergoing coronary artery bypass grafting and early tracheal extubation. Anesth Analg. 1998;87(1):27-33. [pmid: 9661540].
Chaney MA, Nikolov MP, Blakeman BP, et al. Hemodynamic effects of methylprednisolone in patients undergoing cardiac operation and early extubation. Ann Thorac Surg. 1999;67(4):1006-11. [pmid: 10320243].
Chao DC, Scheinhorn DJ, Stearn-Hassenpflug M. Patient-ventilator trigger asynchrony in prolonged mechanical ventilation. Chest. 1997;112(6):1592-9. [pmid: 9404759].
Chatila W, Ani S, Guaglianone D, et al. Cardiac ischemia during weaning from mechanical ventilation. Chest. 1996a;109(6):1577-83.
Chatila W, Jacob B, Guaglianone D, et al. The unassisted respiratory rate-tidal volume ratio accurately predicts weaning outcome. Am J Med. 1996b;101(1):61-7.
Cheng DC, Karski J, Peniston C, et al. Morbidity outcome in early versus conventional tracheal extubation after coronary artery bypass grafting: A prospective randomized controlled trial. J Thorac Cardiovasc Surg. 1996a;112(3):755-64.
Cheng DC, Karski J, Peniston C, et al. Early tracheal extubation after coronary artery bypass graft surgery reduces costs and improves resource use. A prospective, randomized, controlled trial. Anesthesiology. 1996b;85(6):1300-10.
Chong JL, Grebenik C, Sinclair M, et al. The effect of a cardiac surgical recovery area on the timing of extubation. J Cardiothorac Vasc Anesth. 1993;7(2):137-41. [pmid: 8477015].
Chopin C, Chambrin MC, Mangalaboyi J, et al. Carbon dioxide mandatory ventilation (CO2MV): A new method for weaning from mechanical ventilation. Description and comparative clinical study with I.M.V. and T. tube method in COPD patient. Int J Clin Monit Comput. 1989;6(1):11-9. [pmid: 2498449].
Cook DJ, Walters S, Brun-Buisson C, et al., for the Clinical Trials Group. Ventilator-associated pneumonia: Incidence and risk factors. Ann Int Med. 1998;129(6):433-40. [pmid: 9735080].
Darmon JY, Rauss A, Dreyfuss D, et al. Evaluation of risk factors for laryngeal edema after tracheal extubation in adults and its prevention by dexamethasone. A placebo-controlled, double-blind, multicenter study. Anesthesiology. 1992;77(2):245-51. [pmcid: 60651]. [pmid: 1642342].
Davis S, Potgieter PD, Linton DM. Mandatory minute volume weaning in patients with pulmonary pathology. Anaesth Intensiv Care. 1989;17(2):170-4.
DeHaven CB, Kirton OC, Morgan JP, et al. Breathing measurement reduces false-negative classification of tachypneic preextubation trial failures. Crit Care Med. 1996;24(6):976-80. [pmid: 8681601].
Del Rosario N, Sassoon CS, Chetty KG, et al. Breathing pattern during acute respiratory failure and recovery. Eur Respir J. 1997;10(11):2560-5. [pmid: 9426095].
Delooz HH. Factors influencing successful discontinuance of mechanical ventilation after open heart surgery: A clinical study of 41 patients. Crit Care Med. 1976;4(5):265-70. [pmid: 975853].
Djunaedi H, Cardinal P, Greffe-Laliberte G, et al. Does a ventilatory management protocol improve the care of ventilated patients?. Respir Care. 1997;42(6):604-10.
Doering LV. Relationship of age, sex, and procedure type to extubation outcome after heart surgery. Heart Lung. 1997;26(6):439-47. [pmid: 9431490].
Doering LV, Imperial-Perez F, Monsein S, et al. Preoperative and postoperative predictors of early and delayed extubation after coronary artery bypass surgery. Am J Crit Care. 1998;7(1):37-44. [pmid: 9429682].
Dojat M, Harf A, Touchard D, et al. Evaluation of a knowledge-based system providing ventilatory management and decision for extubation. Am J Respir Crit Care Med. 1996;153(3):997-1004. [pmid: 8630586].
Dumas A, Dupuis GH, Searle N, et al. Early versus late extubation after coronary artery bypass grafting: Effects on cognitive function. J Cardiothorac Vasc Anesth. 1999;13(2):130-5. [pmid: 10230943].
el-Khatib MF, Baumeister B, Smith PG, et al. Inspiratory pressure/maximal inspiratory pressure: Does it predict successful extubation in critically ill infants and children?. Intensiv Care Med. 1996;22(3):264-8.
Ely EW, Baker AM, Dunagan DP, et al. Effect on the duration of mechanical ventilation of identifying patients capable of breathing spontaneously. N Engl J Med. 1996;335(25):1864-9. [pmid: 8948561].
Ely EW, Baker AM, Evans GW, et al. The prognostic significance of passing a daily screen of weaning parameters. Intensiv Care Med. 1999;25(6):581-7.
Engelman RM, Rousou JA, Flack JE, et al. Fast-track recovery of the coronary bypass patient. Ann Thorac Surg. 1994;58(6):1742-6. [pmid: 7979747].
Engoren MC, Kraras C, Garzia F. Propofol-based versus fentanyl-isoflurane-based anesthesia for cardiac surgery. J Cardiothorac Vasc Anesth. 1998;12(2):177-81. [pmid: 9583550].
Engoren M, Buderer NF, Zacharias A, et al. Variables predicting reintubation after cardiac surgical procedures. Ann Thorac Surg. 1999;67(3):661-5. [pmid: 10215207].
Epstein SK. Etiology of extubation failure and the predictive value of the rapid shallow breathing index. Am J Respir Crit Care Med. 1995;152(2):545-9. [pmid: 7633705].
Epstein SK, Ciubotaru RL. Influence of gender and endotracheal tube size on preextubation breathing pattern [published erratum appears in Am J Respir Crit Care Med 1997 Jun;155(6):2115]. Am J Respir Crit Care Med. 1996;154(6 Pt 1):1647-52. [pmid: 8970349].
Esen F, Denkel T, Telci L, et al. Comparison of pressure support ventilation (PSV) and intermittent mandatory ventilation (IMV) during weaning in patients with acute respiratory failure. Adv Exp Med Biol. 1992;317:371-6. [pmid: 1288147].
Esteban A, Alia I, Ibanez J, et al. Modes of mechanical ventilation and weaning. A national survey of Spanish hospitals. The Spanish Lung Failure Collaborative Group. Chest. 1994;106(4):1188-93. [pmid: 7924494].
Esteban A, Frutos F, Tobin MJ, et al. A comparison of four methods of weaning patients from mechanical ventilation. Spanish Lung Failure Collaborative Group. N Engl J Med. 1995;332(6):345-50. [pmid: 7823995].
Esteban A, Alia I, Gordo F, et al. Extubation outcome after spontaneous breathing trials with T-tube or pressure support ventilation. The Spanish Lung Failure Collaborative Group [published erratum appears in Am J Respir Crit Care Med 1997 Dec; 156(6): 2028]. Am J Respir Crit Care Med. 1997;156(2 Pt 1):459-65. [pmid: 9279224].
Esteban A, Alia I, Tobin MJ, et al. Effect of spontaneous breathing trial duration on outcome of attempts to discontinue mechanical ventilation. Spanish Lung Failure Collaborative Group. Am J Respir Crit Care Med. 1999;159(2):512-8. [pmid: 9927366].
Fagon JY, Chastre J, Vuagnat A, et al. Nosocomial pneumonia and mortality among patients in intensive Care units. JAMA. 1996;275(11):866-9. [pmid: 8596225].
Farias JA, Alia I, Esteban A, et al. Weaning from mechanical ventilation in pediatric intensive care patients. Intensiv Care Med. 1998;24(10):1070-5.
Feeley TW, Saumarez R, Klick JM, et al. Positive end-expiratory pressure in weaning patients from controlled ventilation. A prospective randomised trial. Lancet. 1975;2(7938):725-9. [pmid: 52767].
Fisher MM, Raper RF. The "cuff-leak" test for extubation. Anaesthesia. 1992;47(1):10-2. [pmid: 1536393].
Fleiss J. The statistical basis of meta-analysis. Stat Methods Med Res. 1993:2121-45.
Foster GH, Conway WA, Pamulkov N, et al. Early extubation after coronary artery bypass: Brief report. Crit Care Med. 1984;12(11):994-6. [pmid: 6333969].
Freezer N, Butt W, Phelan P. Steroids in croup: Do they increase the incidence of successful extubation?. Anaesth Intensiv Care. 1990;18(2):224-8.
Frutos F, Alia I, Esteban A, et al. Clinical changes during a T-tube weaning trial. Med Intensiv. 1995;19(7):343-8.
Gandia F, Blanco J. Evaluation of indexes predicting the outcome of ventilator weaning and value of adding supplemental inspiratory load. Intensiv Care Med. 1992;18(6):327-33.
Gaussorgues P, Boyer F, Piperno D, et al. [Laryngeal edema after extubation. Do corticosteroids play a role in its prevention?]. [Fre]. Presse Med. 1987;16(31):1531-2. [pmid: 2958819].
Girault C, Daudenthun I, Chevron V, et al. Noninvasive ventilation as a systematic extubation and weaning technique in acute-on-chronic respiratory failure: A prospective, randomized controlled study. Am J Respir Crit Care Med. 1999;160(1):86-92. [pmid: 10390384].
Gologorskii VA, Gelfand BR, Stamov VI, et al. [Cessation of prolonged artificial ventilation of the lungs and transition to spontaneous respiration of surgical patients]. [Rus]. Anesteziol Reanimatol. 1997;(1):4-10. [pmid: 9173817].
Goodnough-Hanneman SK. Predictors of weaning from mechanical ventilation. Heart Lung: J Crit Care. 1992;21(3).
Goodnough-Hanneman SK. Multidimensional predictors of success or failure with early weaning from mechanical ventilation after cardiac surgery. Nurs Res. 1994;43(1):4-10. [pmid: 8295839].
Gust R, Gottschalk A, Schmidt H, et al. Effects of continuous (CPAP) and bi-level positive airway pressure (BiPAP) on extravascular lung water after extubation of the trachea in patients following coronary artery bypass grafting. Intensiv Care Med. 1996;22(12):1345-50.
Habib RH, Zacharias A, Engoren M. Determinants of prolonged mechanical ventilation after coronary artery bypass grafting. Ann Thorac Surg. 1996;62(4):1164-71. [pmid: 8823107].
Harel Y, Vardi A, Quigley R, et al. Extubation failure due to post-extubation stridor is better correlated with neurologic impairment than with upper airway lesions in critically ill pediatric patients. Int J Pediatr Otorhinolaryngol. 1997;39(2):147-58. [pmid: 9104623].
Hastings PR, Bushnell LS, Skillman JJ, et al. Cardiorespiratory dynamics during weaning with IMV versus spontaneous ventilation in good-risk cardiac-surgery patients. Anesthesiology. 1980;53(5):429-31. [pmid: 6968523].
Hilberman M, Kamm B, Lamy M, et al. An analysis of potential physiological predictrs of respiratory adequacy following cardiac surgery. J Thorac Cardiovasc Surg. 1976;717:11-20.
Hilbert G, Gruson D, Portel L, et al. Noninvasive pressure support ventilation in COPD patients with postextubation hypercapnic respiratory insufficiency. Eur Respir J. 1998a;11(6):1349-53.
Hilbert G, Gruson D, Portel L, et al. Airway occlusion pressure at 0.1 s (P0.1) after extubation: An early indicator of postextubation hypercapnic respiratory insufficiency. Intensiv Care Med. 1998b;24(12):1277-82.
Ho LI, Harn HJ, Lien TC, et al. Postextubation laryngeal edema in adults. Risk factor evaluation and prevention by hydrocortisone. Intensiv Care Med. 1996;22(9):933-6.
Holliday JE, Hyers TM. The reduction of weaning time from mechanical ventilation using tidal volume and relaxation biofeedback. Am Rev Respir Dis. 1990;141(5 Pt 1):1214-20. [pmid: 2187384].
Horst HM, Mouro D, Hall JR, et al. Decrease in ventilation time with a standardized weaning process. Arch Surg. 1998;133(5):483-9. [pmid: 9605909].
Ingersoll GL, Grippi MA. Preoperative pulmonary status and postoperative extubation outcome of patients undergoing elective cardiac surgery. Heart Lung. 1991;20(2):137-43. [pmid: 2004924].
Irwig L, Tosteson A, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Int Med. 1994;120:667-76. [pmid: 8135452].
Jablonski RS. The experience of being mechanically ventilated. Qual Health Res. 1994;4(2):186-207.
Jabour ER, Rabil DM, Truwit JD, et al. Evaluation of a new weaning index based on ventilatory endurance and the efficiency of gas exchange. Am Rev Respir Dis. 1991;144(3 Pt 1):531-7. [pmid: 1892291].
Jacob B, Chatila W, Manthous CA. The unassisted respiratory rate/tidal volume ratio accurately predicts weaning outcome in postoperative patients. Crit Care Med. 1997;25(2):253-7. [pmid: 9034260].
Jaeschke R, Guyatt G, Sackett D, et al., for the Evidence-Based Medicine Working Group. Users' guide to the medical literature: How to use an article about a diagnostic test A. Are the results of the study valid?. JAMA. 1994a;271(5):389-91.
Jaeschke R, Guyatt G, Sackett D, et al., for the. Evidence-Based Medicine Working Group. Users' guides to the medical literature: How to use an article about a diagnostic test B. What are the results and will they help me in caring for my patients?. JAMA. 1994b;271(9):703-7.
Jenny J, Logan J. Analyzing expert nursing practice to develop a new nursing diagnosis dysfunctional ventilatory weaning response. In: Carroll-Johnson RM, ed. Classification of nursing diagnoses: Proceedings of the 9th conference; 1990. Orlando, FL. Lippincott: 1991. p. 133-40.
Jenny J, Logan J. Promoting ventilator independence: A grounded theory perspective. Dimensions Crit Care Nurs. 1994;13(1):29-37.
Jenny J, Logan J. Caring and comfort metaphors used by patients in critical care. Image J Nurs Sch. 1996;28(4):349-52. [pmid: 8987283].
Jiang JS, Kao SJ, Wang SN. Effect of early application of biphasic positive airway pressure on the outcome of extubation in ventilator weaning. Respirology. 1999;4(2):161-5. [pmid: 10382235].
Johnson D, Thomson D, Mycyk T, et al. Respiratory outcomes with early extubation after coronary artery bypass surgery. J Cardiothorac Vasc Anesth. 1997;11(4):474-80. [pmid: 9187998].
Jones DP, Byrne P, Morgan C, et al. Positive end-expiratory pressure vs T-piece. Extubation after mechanical ventilation. Chest. 1991;100(6):1655-9. [pmid: 1959410].
Jounieaux V, Duran A, Levi-Valensi P. Synchronized intermittent mandatory ventilation with and without pressure support ventilation in weaning patients with COPD from mechanical ventilation [published erratum appears in Chest 1994 Sep;106(3):984]. Chest. 1994;105(4):1204-10. [pmid: 8162750].
Jubran A, Tobin MJ. Pathophysiologic basis of acute respiratory distress in patients who fail a trial of weaning from mechanical ventilation. Am J Respir Crit Care Med. 1997;155(3):906-15. [pmid: 9117025].
Kanter RK, Bove EL, Tobin JR, et al. Prolonged mechanical ventilation of infants after open heart surgery. Crit Care Med. 1986;14(3):211-4. [pmid: 3943337].
Kennedy SK, Weintraub RM, Skillman JJ. Cardiorespiratory and sympathoadrenal responses during weaning from controlled ventilation. Surgery. 1977;82(2):233-40. [pmcid: 101389]. [pmid: 877867].
Khan N, Brown A, Venkataraman ST. Predictors of extubation success and failure in mechanically ventilated infants and children. Crit Care Med. 1996;24(9):1568-79. [pmid: 8797633].
Kline JL, Zimnicki GL, Antonenko DR, et al. The use of calculated relative inspiratory effort as a predictor of outcome in mechanical ventilation weaning trials. Respir Care. 1987;32(10):870-6.
Kollef MH, Shapiro SD, Silver P, et al. A randomized, controlled trial of protocol-directed versus physician-directed weaning from mechanical ventilation. Crit Care Med. 1997;25(4):567-74. [pmid: 9142019].
Kollef MH, Horst HM, Prang L, et al. Reducing the duration of mechanical ventilation: Three examples of change in the intensive care unit. New Horizons. 1998;6(1):52-60. [pmid: 9508258].
Krieger BP, Ershowsky PF, Becker DA, et al. Evaluation of conventional criteria for predicting successful weaning from mechanical ventilatory support in elderly patients. Crit Care Med. 1989;17(9):858-61. [pmid: 2766756].
Krieger BP, Isber J, Breitenbucher A, et al. Serial measurements of the rapid-shallow-breathing index as a predictor of weaning outcome in elderly medical patients. Chest. 1997;112(4):1029-34. [pmid: 9377913].
Laussen PC, Reid RW, Stene RA, et al. Tracheal extubation of children in the operating room after atrial septal defect repair as part of a clinical practice guideline. Anesth Analg. 1996;82(5):988-93. [pmid: 8610911].
Lee CK, Chien TJ, Hsu JC, et al. The effect of acupuncture on the incidence of postextubation laryngospasm in children. Anaesthesia. 1998;53(9):917-20. [pmid: 9849290].
Lee JH, Kim KH, vanHeeckeren DW, et al. Cost analysis of early extubation after coronary bypass surgery. Surgery. 1996;120(4):611-7. [pmid: 8862368].
Lee KH, Hui KP, Chan TB, et al. Rapid shallow breathing (frequency-tidal volume ratio) did not predict extubation outcome. Chest. 1994;105(2):540-3. [pmid: 8306759].
Leitch EA, Moran JL, Grealy B. Weaning and extubation in the intensive care unit. Clinical or index-driven approach?. Intensiv Care Med. 1996;22(8):752-9.
Linton DM, Potgieter PD, Davis S, et al. Automatic weaning from mechanical ventilation using an adaptive lung ventilation controller. Chest. 1994;106(6):1843-50. [pmid: 7988211].
Littenberg B, Moses L. Estimating diagnostic accuracy from multiple conflicting reports: A new meta-analytic method. Med Decis Making. 1993;13:313-21. [pmid: 8246704].
Logan J, Jenny J. Deriving a new nursing diagnosis through qualitative research: dysfunctional ventilatory weaning response. Nurs Diagn. 1990;1(1):37-43. [pmid: 2350526].
Logan J, Jenny J. Interventions for the nursing diagnosis dysfunctional ventilatory weaning response: A qualitative study. In: Carroll-Johnson RM, ed. Classification of nursing diagnoses: Proceedings of the 9th conference, Orlando, FL, 1990. Lippincott: 1991. p. 141-7.
Logan J, Jenny J. Qualitative analysis of patients' work during mechanical ventilation and weaning. Heart Lung. 1997;26(2):140-7. [pmid: 9090519].
London M, Shroyer A, Jernigan V, et al. Fast-track cardiac surgery in a Department of Veterans Affairs patient population. Ann Thorac Surg. 1997;64(134).
London MJ, Shroyer AL, Coll JR, et al. Early extubation following cardiac surgery in a veterans population. Anesthesiology. 1998;88(6):1447-58. [pmid: 9637636].
Lowry LW, Anderson B. Neuman's framework and ventilator dependency: A pilot study. Nurs Sci Q. 1993;6(4):195-200. [pmid: 8265053].
McDonald NJ, Lavelle P, Gallacher WN, et al. Use of the oxygen cost of breathing as an index of weaning ability from mechanical ventilation. Intensiv Care Med. 1988;14(1):50-4.
Meade MO, Cook DJ. The etiology, consequences, and prevention of barotrauma: A critical review of the literature. Clin Intensiv Care. 1995;6(4):166-73.
Meade MO, Cook DJ, Kernerman P, et al. How to use articles about harm: The relationship between high tidal volumes, ventilating pressures, and ventilator-induced lung injury. Crit Care Med. 1997;25(11):1915-22. [pmid: 9366779].
Mendel JG, Khan FA. Psychological aspects of weaning from mechanical ventilation. Psychosomatics. 1980;21(6):465-71. [pmid: 7394156].
Menzel LK. A comparison of patients' communication-related responses during intubation and after extubation. Heart Lung. 1997;26(5):363-71. [pmid: 9315465].
Menzies R, Gibbons W, Goldberg P. Determinants of weaning and survival among patients with COPD who require mechanical ventilation for acute respiratory failure. Chest Cardiopul J. 1989;95(2):398-405.
Mergoni M, Costa A, Primavera S, et al. [Assessment of various new predictive parameters of the outcome of mechanical ventilation weaning]. [Ita]. Minerva Anestesiol. 1996;62(5):153-64. [pmid: 9045094].
Michalopoulos A, Nikolaides A, Antzaka C, et al. Change in anaesthesia practice and postoperative sedation shortens ICU and hospital length of stay following coronary artery bypass surgery. Respir Med. 1998;92(8):1066-70. [pmid: 9893777].
Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
Mohsenifar Z, Hay A, Hay J, et al. Gastric intramural pH as a predictor of success or failure in weaning patients from mechanical ventilation. Ann Int Med. 1993;119(8):794-8. [pmid: 8166793].
Moody LE, Lowry L, Yarandi H, et al. Psychophysiologic predictors of weaning from mechanical ventilation in chronic bronchitis and emphysema. Clinical Nurs Res. 1997;6(4):311-30. [pmid: 9384053].
Moses L, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: Data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-316. [pmid: 8210827].
Nava S, Zanotti E, Rubini F. Weaning and outcome from mechanical ventilation. Monaldi Arch Chest Dis. 1994;49(6):530-2. [pmid: 7711709].
Nava S, Rubini F, Zanotti E, et al. Survival and prediction of successful ventilator weaning in COPD patients requiring mechanical ventilation for more than 21 days. Eur Respir J. 1994;7(9):1645-52. [pmid: 7995395].
Nava S, Ambrosino N, Clini E, et al. Noninvasive mechanical ventilation in the weaning of patients with respiratory failure due to chronic obstructive pulmonary disease. A randomized, controlled trial. Ann Int Med. 1998;128(9):721-8. [pmid: 9556465].
Niehoff J, DelGuercio C, LaMorte W, et al. Efficacy of pulse oximetry and capnometry in postoperative ventilatory weaning. Crit Care Med. 1988;16(7):701-5. [pmid: 3131068].
Ochiai R, Shimada M, Takeda J, et al. Contribution of rib cage and abdominal movement to ventilation for successful weaning from mechanical ventilation. Acta Anaesthesiol Scan. 1993;37(2):131-6.
Oh TE, Bhatt S, Lin ES, et al. Plasma catecholamines and oxygen consumption during weaning from mechanical ventilation. Intensiv Care Med. 1991;17(4):199-203.
Papazian L, Bregeon F, Thirion X, et al. Effect of ventilator-associated pneumonia on mortality and morbidity. Am J Respir Crit Care Med. 1996;154(1):91-7. [pmid: 8680705].
Patel RG, Petrini MF, Dwyer TM. Work of breathing during weaning from ventilation: Does extending weaning with continuous positive airway pressure confer any advantage?. Respir Care. 1999;44(4):421-7.
Peters RM, Brimm JE, Utley JR. Predicting the need for prolonged ventilatory support in adult cardiac patients. J Thorac Cardiovasc Surg. 1979;77(2):175-82. [pmid: 310915].
Pichard C, Kyle U, Chevrolet JC, et al. Lack of effects of recombinant growth hormone on muscle function in patients requiring prolonged mechanical ventilation: A prospective, randomized, controlled study. Crit Care Med. 1996;24(3):403-13. [pmid: 8625627].
Pochard F, Lanore JJ, Bellivier F, et al. Subjective psychological status of severely ill patients discharged from mechanical ventilation. Clin Intensiv Care. 1995;(2):57-61.
Quasha AL, Loeber N, Feeley TW, et al. Postoperative respiratory care: A controlled trial of early and late extubation following coronary-artery bypass grafting. Anesthesiology. 1980;52(2):135-41. [pmid: 6986104].
Quigley RL, Reitknecht FL. A coronary artery bypass "fast-track" protocol is practical and realistic in a rural environment. Ann Thorac Surg. 1997;64(3):706-9. [pmid: 9307461].
Rady MY, Ryan T. Perioperative predictors of extubation failure and the effect on clinical outcome after cardiac surgery. Crit Care Med. 1999;27(2):340-7. [pmid: 10075059].
Rathgeber J, Schorn B, Falk V, et al. The influence of controlled mandatory ventilation (CMV), intermittent mandatory ventilation (IMV) and biphasic intermittent positive airway pressure (BIPAP) on duration of intubation and consumption of analgesics and sedatives. A prospective analysis in 596 patients following adult cardiac surgery. Eur J Anaesthesiol. 1997;14(6):576-82. [pmid: 9466092].
Reyes A, Vega G, Blancas R, et al. Early vs conventional extubation after cardiac surgery with cardiopulmonary bypass. Chest. 1997;112(1):193-201. [pmid: 9228376].
Rivera L, Weissman C. Dynamic ventilatory characteristics during weaning in postoperative critically ill patients. Anesth Analg. 1997;84(6):1250-5. [pmid: 9174302].
Rotello LC, Warren J, Jastremski MS, et al. A nurse-directed protocol using pulse oximetry to wean mechanically ventilated patients from toxic oxygen concentrations. Chest. 1992;102(6):1833-5. [pmid: 1446498].
Sahn SA, Lakshminarayan S. Bedside criteria for discontinuation of mechanical ventilation. Chest. 1973;63(6):1002-5. [pmid: 4514488].
Saito S, Tokioka H, Saeki S, et al. [Is airway occlusion pressure useful to predict successful weaning from mechanical ventilation in patients with acute respiratory failure?]. [Jap]. Kokyu To Junkan. 1991;39(2):143-5. [pmid: 2017594].
Saldias F, Castellon JM, Garayar B, et al. [Predictor indices of early extubation in mechanical ventilation in patients treated with heart surgery]. [Spa]. Rev Med Chile. 1996;124(8):959-66. [pmid: 9196996].
Sassoon CS, Mahutte CK. Airway occlusion pressure and breathing pattern as predictors of weaning outcome. Am Rev Respir Dis. 1993;148(4 Pt 1):860-6. [pmid: 8214939].
Saura P, Blanch L, Mestre J, et al. Clinical consequences of the implementation of a weaning protocol. Intensiv Care Med. 1996a;22(10):1052-6.
Saura P, Blanch L, Lucangelo U, et al. Use of capnography to detect hypercapnic episodes during weaning from mechanical ventilation. Intensiv Care Med. 1996b;22(5):374-81.
Schirmer U, Calzia E, Lindner KH, et al. Right ventricular function during weaning from respirator af1ter coronary artery bypass grafting. Comparison of two different weaning techniques. Chest. 1994;105(5):1352-6. [pmid: 8181318].
Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
Shackford SR, Virgilio RW, Peters RM. Early extubation versus prophylactic ventilation in the high risk patient: A comparison of postoperative management in the prevention of respiratory complications. Anesth Analg. 1981;60(2):76-80. [pmid: 7053123].
Shikora SA, Bistrian BR, Borlase BC, et al. Work of breathing: reliable predictor of weaning and extubation. Crit Care Med. 1990;18(2):157-62. [pmid: 2298006].
Silbert BS, Santamaria JD, O'Brien JL, et al. Early extubation following coronary artery bypass surgery: A prospective randomized controlled trial. The Fast Track Cardiac Care Team. Chest. 1998;113(6):1481-8. [pmid: 9631781].
Simel D, Samsa G, Matchar D. Likelihood ratios with confidence: Sample size estimation for diagnostic test studies. J Clin Epidemiol. 1991;44(8):763-70. [pmid: 1941027].
Slutsky AS, Tremblay LN. Multiple system organ failure. Is mechanical ventilation a contributing factor?. Am J Respir Crit Care Med. 1998;157(6 Pt 1):1721-5. [pmid: 9620897].
Strickland JH, Jr., Hasson JH. A computer-controlled ventilator weaning system: A clinical trial. Chest. 1993;103(4):1220-6. [pmid: 8131469].
Stroetz RW, Hubmayr RD. Tidal volume maintenance during weaning with pressure support. Am J Respir Crit Care Med. 1995;152(3):1034-40. [pmid: 7663780].
Sugahara M, Mukaida K, Kurata J, et al. [General anesthesia with propofol and fentanyl for adult cardiac surgery]. [Jap]. Masui. 1999;48(2):162-7. [pmid: 10087825].
Tahvanainen J, Salmenpera M, Nikki P. Extubation criteria after weaning from intermittent mandatory ventilation and continuous positive airway pressure. Crit Care Med. 1983;11:702-7. [pmid: 6411431].
Takala J, Ruokonen E, Webster N, et al. Increased mortality associated with growth hormone treatment in critically ill adults. N Engl J Med. 1999;341:785-92. [pmid: 10477776].
Tellez DW, Galvis AG, Storgion SA, et al. Dexamethasone in the prevention of postextubation stridor in children. J Pediatr. 1991;118(2):289-94. [pmid: 1993963].
Tempe D, Cooper A, Mohan JC, et al. Closed mitral valvotomy and elective ventilation in the postoperative period: Effect of mild hypercarbia on right ventricular function. J Cardiothorac Vasc Anesth. 1995;9(5):552-7. [pmid: 8547558].
Thorens JB, Kaelin RM, Jolliet P, et al. Influence of the quality of nursing on the duration of weaning from mechanical ventilation in patients with chronic obstructive pulmonary disease. Crit Care Med. 1995;23(11):1807-15. [pmid: 7587255].
Tomlinson JR, Miller KS, Lorch DG, et al. A prospective comparison of IMV and T-piece weaning from mechanical ventilation. Chest. 1989;96(2):348-52. [pmid: 2666046].
Tong DA. Weaning patients from mechanical ventilation. A knowledge-based system approach. Comput Methods Programs Biomed. 1991;35(4):267-78. [pmid: 1752122].
Vallverdu I, Calaf N, Subirana M, et al. Clinical characteristics, respiratory functional parameters, and outcome of a two-hour T-piece trial in patients weaning from mechanical ventilation. Am J Respir Crit Care Med. 1998;158(6):1855-62. [pmid: 9847278].
van den Berg B, Bogaard JM, Hop WC. High fat, low carbohydrate, enteral feeding in patients weaning from the ventilator. Intensiv Care Med. 1994;20(7):470-5.
Vincent J, Bihari D, Suter PM, et al. The prevalence of nosocomial infection in intensive care units in Europe (EPIC). JAMA. 1995;274:639-44. [pmid: 7637145].
Wood G, MacLeod B, Moffatt S. Weaning from mechanical ventilation: Physician-directed vs a respiratory-therapist-directed protocol. Respir Care. 1995;(3):219-24.
Wunderlich RJ, Perry A, Lavin MA, et al. Patients' perceptions of uncertainty and stress during weaning from mechanical ventilation. Dimensions Crit Care Nurs. 1999;18(1):2-10.
Yang KL. Inspiratory pressure/maximal inspiratory pressure ratio: A predictive index of weaning outcome. Intensiv Care Med. 1993;19(4):204-8.
Yang KL, Tobin MJ. A prospective study of indexes predicting the outcome of trials of weaning from mechanical ventilation. N Engl J Med. 1991;324(21):1445-50. [pmid: 2023603].
Zanotti E, Rubini F, Iotti G, et al. Elevated static compliance of the total respiratory system: Early predictor of weaning unsuccess in severed COPD patients mechanically ventilated. Intensiv Care Med. 1995;21(5):399-405.