# Summary

## Overview

The majority of critically ill patients in most modern intensive care units (ICUs) require a period of mechanical ventilation. Prolonged mechanical ventilation is associated with nosocomial pneumonia, cardiac-associated morbidity, and death. Prematurely discontinuing mechanical ventilation may result in reintubation which is associated with complications similar to prolonged ventilation. Thus, optimal weaning-minimizing the duration of mechanical ventilation without incurring substantial risk of reintubation and thus preventing important complications-is a crucial part of the management of critically ill patients. Therefore, the Agency for Healthcare Research and Quality (AHRQ) asked us to address the following questions:

1 When should weaning be initiated?
2 What criteria should be used to initiate the weaning process?
3 What are the most effective methods of weaning from mechanical ventilation?
4 What are the optimal roles of nonphysician health care professionals in facilitating safe and expeditious weaning?
5 What is the value of clinical practice algorithms and computers in expediting weaning?

## Reporting the Evidence

We resolved to retrieve all randomized trials and the most relevant clinical observational studies that addressed the AHRQ review questions. Conceptually, we were interested in any patients receiving mechanical ventilation, in any strategies designed to facilitate weaning and extubation, in predictors of weaning and extubation in all critically ill patients, and in predictors of the duration of weaning in patients with chronic obstructive pulmonary disease (COPD) or patients following cardiac surgery.

### Populations

We included all studies of adult and pediatric patients who were mechanically ventilated and had either an endotracheal tube or tracheostomy tube. We excluded studies of highly specific populations and studies in neonates.

### Settings

We included studies conducted in intensive care units (ICUs), intermediate care units, stepdown units, and postanesthetic recovery rooms. We excluded studies of home ventilation for children or adults and chronic ventilation settings.

### Interventions

We included any ventilation or weaning strategy (e.g., mode, method, procedure, protocol, timing, operator, computer, tracheostomy, noninvasive ventilation modes, adjunctive holistic aids, and other miscellaneous approaches) geared to facilitate weaning and/or extubation. We excluded interventions focused on mechanical ventilation methods and interventions whose influence on the duration of ventilation has already been summarized in a recent systematic review (e.g., sedation in the ICU and optimal timing of tracheotomy).

### Predictors

We included predictors of weaning and/or extubation success and predictors of duration of mechanical ventilation in cardiac surgery and COPD patients. We excluded predictors of self-extubation.

### Outcomes

We included all clinical outcomes. We excluded studies which reported exclusively physiologic outcomes. We included studies reporting the endpoint of patients' experiences and nurses' assessments of patients' experiences to address question 4 regarding the important role of nurses in optimizing the weaning process.

## Methodology

To identify relevant studies, we searched MEDLINE, EMBASE, HealthSTAR, CINAHL, the Cochrane Controlled Trials Registry, and the Cochrane Data Base of Systematic Reviews from 1971 to 1998. We also examined reference lists and personal files and hand searched Respiratory Care. We did not explicitly search for unpublished literature. We retrieved all articles that either of two reviewers of the titles and abstracts considered possibly eligible. The same two reviewers examined the full text and made final decisions regarding eligibility based on the inclusion and exclusion criteria described above.

Five respiratory therapists and five intensivists participated in data abstraction and in rating the methodologic quality of all eligible randomized trials or nonrandomized controlled cohort studies addressing treatment issues, and all studies providing quantitative data concerning predictors of weaning and extubation. Two reviewers abstracted the data and assessed the methodologic quality of each study.

Methodologic features of randomized trials that we abstracted included the method of randomization and whether randomization was concealed; the extent to which groups were similar with respect to important prognostic factors; whether investigators conducted an intention to treat analysis; whether patients, clinicians, and those assessing outcome were blind to allocation; the extent to which the groups received similar cointerventions; and the reporting of the reasons for study withdrawal.

For nonrandomized controlled clinical trials, we considered the extent to which groups were similar with respect to important prognostic factors, whether the investigators adjusted for differences in prognostic factors, and the extent to which the groups received similar cointerventions.

For studies addressing predictors of weaning success, we considered whether investigators enrolled a representative sample of patients and whether those making weaning decisions or assessing outcomes were blind to predictor variables.

For qualitative studies, we considered whether the choice of participants was relevant to the research question and if their selection was well reasoned, whether the data collection methods were appropriate for the research objectives, whether the data collection was comprehensive enough to support rich and robust descriptions of the observed events, and whether the data were appropriately analyzed and the findings adequately corroborated.

To synthesize the data from randomized trials comparing weaning interventions we abstracted or, when necessary, calculated effect sizes in terms of relative risks and associated 95 percent confidence intervals (CIs) for binary outcomes and mean differences and 95 percent CIs for continuous variables. We reviewed the interventions and outcomes and decided when it was legitimate to pool across studies and when it was not. When pooling was not appropriate, we categorized studies according to similarity of interventions. All our pooled analyses are based on a random effects model that includes differences between studies in calculating the variance estimate provided the strategy for final estimates of all treatment effects. For nonrandomized studies that compared alternative weaning interventions, we used similar methodology for calculating point estimates and CIs for individual studies but made no attempt to pool data across studies.

For observational studies addressing prediction of successful weaning and duration of ventilation, we categorized studies according to the outcome of interest and, for each predictor in each study in which the data were available, we constructed a 2X2 table examining the presence or absence of the predictor in relation to the success or failure of the weaning process. This procedure allowed calculation of the sensitivity and specificity of the tests and their associated 95 percent CIs as well as odds ratios and their 95 percent CIs and the associated likelihood ratios. We then organized the observational studies according to predictors of interest. We defined predictors as relevant if they showed potential for differentiating success from failure and retained all predictors for which results were presented in 2X2 tables if there was an associated likelihood ratio (LR) of greater than 2 or lower than 0.5. When results were presented as means and standard deviations of the success and failure groups, we included predictors if the difference in means between the two groups was greater than one-half of the smaller of the standard deviations of the two groups. Where appropriate, we pooled the observational data to narrow the 95 percent CIs.

## Findings

- We reviewed 154 articles.
- The issue of the optimal start of weaning is confounded by alternative definitions of weaning: one reasonable conceptualization is weaning beginning with the onset of mechanical ventilation. Research to date suggests the best answer to "when to start weaning" is to develop a protocol implemented by nurses and respiratory therapists that begins testing for the opportunity to reduce support very soon after intubation and reduces support at every opportunity.
- Differences in clinicians' intuitive threshold for reduction or discontinuation of ventilatory support have a greater impact on failure of spontaneous breathing trials, or on reintubation, than do modes of weaning. When clinicians set a high threshold, many patients who could tolerate weaning remain on mechanical support longer than is necessary.
- For stepwise reductions in mechanical support, pressure support mode or multiple daily T-piece trials may be superior to intermittent mandatory ventilation.
- For trials of unassisted breathing, low levels of pressure support may be beneficial.
- There may be substantial benefits to early extubation and institution of noninvasive positive pressure ventilation for patients who are alert, cooperative, and are ready to breathe without an artificial airway.
- Following cardiac surgery, early extubation is unequivocably achieved with a variety of anesthetic interventions and ICU protocols; however, the corresponding reduction in ICU stay is generally small and the impact on complications, though rare, remains unclear.
- The role of computerized weaning protocols has not been established.
- Although steroids can reduce postextubation stridor in children, their impact on reintubation in children and adults remains uncertain.
- Most theoretically plausible predictors of weaning and extubation success have no predictive power. Those with some predictive power include the rapid shallow breathing index, which has been most intensively studied, and occlusion pressure/maximum inspiratory pressure (P_0.1_/MIP) and the compliance, rate, oxygenation, and pressure (CROP) index. However, these are relatively weak predictors of weaning success. Tests are rarely useful in increasing the probability of weaning success; on occasion, they can lead to moderate reductions in the probability of success. In general, weaning predictors were probably found to perform poorly because physicians have already considered the results when they select patients for study.

## Future Research

- Examination of alternative weaning strategies should enroll homogeneous patient groups: those whose likely period of additional ventilation is a few hours, and those whose likely period is a few days. Patients after cardiac surgery constitute another population that should be considered separately.
- In the setting of a high threshold for extubation associated with low failure rates, investigators would require trials of thousands of patients to demonstrate differences between techniques and tens of thousands to demonstrate differences in complications of failed extubation. Investigators should establish plausible event rates before embarking on clinical trials.
- Investigators should attempt to elucidate the tradeoff between decreasing duration of time on a ventilator and the increase in reintubation rates associated with a low weaning threshold (e.g., what reduction in duration of time on a ventilator would warrant an increase in reintubation rates from 5 to 10 percent)? This work should involve attention to the important consequences of prolonged ventilation or reintubation, including nosocomial pneumonia, cardiac morbidity, and death.
- Investigators should launch trials examining the use of noninvasive positive pressure ventilation (NPPV) in reducing the duration of intubation and total mechanical support. Future research should also explore the optimal timing and management of NPPV for weaning purposes, its effect on morbidity (e.g., pneumonia), length of ICU stay, and mortality.
- Investigators should launch additional randomized trials of weaning protocols implemented by respiratory therapists and nurses. These trials should evaluate the differential impact of protocols in different types of patients and in ICUs with different organizational structures (e.g., open versus closed units, teaching versus community hospitals). The influence of different protocols and their impact on ICU and hospital length of stay and costs are important future considerations.
- A more fruitful line of investigation than further research seeking powerful predictors of successful weaning or extubation might be randomized trials of weaning protocols that decrease the duration of mechanical ventilation without substantially increasing rates of failed extubation.