# Acknowledgments

We would like to thank the following individuals who helped with the data abstraction for this systematic review: Aziz Aldawood, Ron Butler, Brad Elms, Lori Hand, Andie Ingram, Carmen Kergl, Jill Randall, Tasnim Sinuff, and Gemini Toprani. Our appreciation is extended to Heiner Bucher, Toshio Fukuoka, Luz Letelier, and Marco Ranieri for the translation of, or data abstraction from, foreign language articles. We also thank Ann McKibbon for her expertise with database searching; Bruce Weaver, Dr. Stephen Walter, and Robin Roberts for their help with the analysis; Marlene Taylor for her help with the preparation of this report; Anne Snider for her administrative guidance; and Drs. Sydney Parker and Alejandro Jadad for their support over the course of this review. We are grateful for the expert peer review suggestions from Drs. Laurent Brochard, Suzanne Burns, Wesley Ely, Scott Epstein, Jesse Hall, John Heffner, Dean Hess, Rolf Hubmayr, Bob Kacmarek, Neil McIntyre, and Peter Pronovost; their suggestions have helped to shape this document. Finally, we appreciate the input of our scientific advisors Drs. Anne Perry and Arthur Slutsky for their expertise and suggestions.