# Conclusions and Future Research

We begin with an observation that is applicable to all trials of alternative ventilation modes and that we have mentioned in our introduction. A major outcome of studies of modes of weaning is failure of weaning, and, in particular, the need for reintubation. Although the need for reintubation is important in and of itself to the extent that patients experience distress as a result of the need for reintubation, the most important consequences are major morbidity such as pneumonia, further lung injury or cardiac complications, and possibly death. To this extent, reintubation is a surrogate outcome. These same complications may result from prolonged ventilation prior to any attempt to extubate. Most studies to date lack the sample size to directly address the important putative consequences of prolonged ventilation and reintubation.

## Controlled Trials of Unassisted Ventilation

Because of small sample sizes and low event rates, most of the randomized trials provide little information about the relative impact of different modes of weaning. The second largest trial (Esteban, Alia, Gordo, et al., 1997) suggests a possible advantage of pressure support over a T-piece trial of spontaneous breathing. The largest trial (Esteban, Alia, Tobin, et al., 1999) suggests a possible advantage to 30-minute T-piece trials over 2-hour T-piece trials with respect to ICU and hospital lengths of stay.

A major theme found in other areas of weaning research emerges from review of the RCTs of unassisted ventilation in patients whom the clinician anticipates are ready for extubation. Irrespective of the interventions being compared, studies examining the impact of short periods of spontaneous breathing with or without some form of support show very different rates of failure of extubation, or reintubation. For instance, the two largest trials (Esteban, Alia, Gordo, et al., 1997; Esteban, Alia, Tobin, et al., 1999) found that 22 percent of 246 patients failed a T-piece weaning trial and of the 192 who were extubated 19 percent required reintubation. In contrast, Jones, Byrne, Morgan, et al. (1991) reported that only 4 percent of 52 patients on a T-piece wean were not extubated and, of those extubated, only 4 percent of 50 required reintubation. These discrepancies suggest that investigators are using quite different criteria when judging if a patient is ready for a trial of spontaneous breathing and different criteria for judging when the trial is a success and extubation is appropriate. When investigators explicitly described their criteria, obvious differences do not emerge. Nevertheless, differences in criteria must partially explain these differences in failure rates. We find the other explanation, that differences in patients leads to discrepancies in success rates, less plausible. This is particularly the case, since studies of predictors of weaning have demonstrated that a wide variety of readily identifiable patient characteristics have minimal or no association with weaning success.

These varying criteria have a number of implications. First, because a particular weaning strategy is superior in a setting where the threshold for a weaning trial, or for extubation, is low does not mean it will be superior in a setting where the threshold is much higher. In fact, where the threshold is high, and failure rates are less than 5 percent, the absolute superiority of one approach over another will be small and perhaps negligible. The other implications have to do with future research.

### Future Research

In the setting of a high threshold and low failure rates, investigators would need to recruit sample sizes in the thousands, or even the tens of thousands, to convincingly demonstrate differences between techniques. Such studies are unlikely to be feasible; even if they were feasible, they would consume substantial resources. Thus, investigators interested in studying optimal use of ventilation strategies in the future should first establish plausible event rates, and if the rates are very low, the investigators should not embark on trials comparing approaches. In situations where event rates are high, it would be reasonable to determine if the Esteban, Frutos, Tobin, et al. (1995) finding of a possible advantage of pressure support over T-piece could be confirmed.

Since the effect of different thresholds appears to overwhelm the impact of alternative ventilation approaches, perhaps investigators should study the use of these alternative thresholds. The RCT literature often specifies that patients become eligible for studies when clinicians judge they are ready for decreasing support or a trial of unassisted ventilation. Since it is this decision that largely determines the outcome, the decision process or criteria warrant intense scrutiny. Some investigators have made their criteria explicit, but apparently similar explicit criteria yield very different results. Thus, there are subtleties in the decisionmaking process that have not yet been elucidated.

On the surface, clinicians who choose a high threshold and reduce failed trials of spontaneous breathing or reintubations to a minimum may be doing the best job. This is not necessarily so. Low rates of failed breathing trials or reintubations are likely to come at the price of prolonged duration of ventilation. Thus, a worthy goal for future research would be to delineate the tradeoff between prolonged time on a ventilator and failed trials of spontaneous breathing and, more importantly, reintubation.

This observation raises the question of what the optimal tradeoff between time on the ventilator and reintubation might be. Interpretation of the results of any study addressing the consequences of differing thresholds would depend on this decision. Were a study to find that a higher threshold increased reintubation rates from 5 to 10 percent (we note that 570 patients per group would be required for an adequately powered study with these event rates) with patients spending a mean of an additional 24 hours on the ventilator, which threshold would be judged optimal? Investigators interested in pursuing the issue of optimal ventilation strategies, and particularly an optimal threshold, should give careful thought to this issue.

## Controlled Trials of Progressive Reduction in Mechanical Support

The issue of different thresholds that was so evident in the RCTs of unassisted ventilation is also relevant in randomized trials of various modes for progressive reduction in mechanical support. For instance, the mean duration of weaning in the T-piece group in the Brochard trial (Brochard, Rauss, Benito, et al., 1994) was 8.5 days and in the Esteban, Frutos, Tobin, et al. (1995) study, 3 days. Here, the major focus of judgment may be issues of patient selection (although the reasons for differences are not apparent from descriptions of the recruiting process) and the judgment as to when the weaning process begins.

The results of these studies suggest the possibility that a multiple daily T-piece wean, or pressure support, may be superior to SIMV. Even for this comparison, however, the CIs on pooled estimates approach no effect. Further, these trials compared particular SIMV weaning regimens. Other weaning regimens using SIMV may produce different results. This is also true of the other weaning modes studied. For instance, the Esteban, Frutos, Tobin, et al. (1995) criteria for weaning may have made it more difficult for patients in the pressure support group to meet extubation criteria than for those in the other groups.

The Jounieaux study (Jounieaux, Duran, and Levi-Valensi, 1994) of synchronized IMV and pressure support versus synchronized IMV suggests the superiority of a regimen that includes pressure support by its finding of a shorter weaning time in the pressure support group. Because of the small sample size and low event rates, the study provides very little information about effects on outcomes of nonextubation or reintubation.

The most dramatic finding in studies of progressive reduction in ventilatory support comes from two small but sound RCTs comparing NPPV with pressure support with or without CPAP. In the larger of these studies (N=50), patients spent a mean of 9 days less in the ICU, and the lower limit of the 95 percent CI, representing the minimal effect of the interventions, was approximately 3 days. The smaller study also reported trends in favor of NPPV. Furthermore, strong trends in mortality and nosocomial pneumonia in these studies favored the NPPV group. The results of two nonrandomized controlled trials are also consistent with these findings.

### Future Research

The trends suggest that SIMV may perform less well than existing alternatives. Additional and ideally larger studies are required to strengthen this tentative conclusion.

The most intriguing finding of the available studies is the suggestion that there may be huge benefits in early extubation and institution of NPPV before patients are ready to breathe without mechanical assistance. However, the studies that addressed this question enrolled a total of fewer than 100 patients. The promising results of these studies are reinforced by the unequivocal results of systematic reviews of NPPV in patients with exacerbations of chronic respiratory disease on the threshold of ventilatory failure that demonstrate mortality benefits in favor of NPPV. Investigation of early NPPV in mechanically ventilated patients should be one of the top priorities in this area.

## Controlled Trials Comparing Alternative Ventilation Modes for Weans Lasting Less Than 48 Hours

Two of the three randomized studies in this category provide further evidence that IMV may be a less advantageous than other methods of decreasing mechanical support (Chopin, Chambrin, Mangalaboyi, et al., 1989; Esen, Denkel, Telci, et al., 1992), and so do the nonrandomized studies (Rathgeber, Schorn, Falk, et al., 1997; Tomlinson, Miller, Lorch, et al., 1989). One RCT provides preliminary data on an innovative technique of reducing support (mimum minute ventilation).

### Future Research

Cardiac surgery patients are best considered separately, and we shall do so in a subsequent section of our conclusions. Examination of alternative weaning strategies might best be done in two homogeneous groups: those whose likely period of additional ventilation is a few hours, and those whose likely period is a few days.

## Controlled Trials Comparing Weaning Protocols to Physician-Directed Weaning

One study of a computer-directed weaning protocol was too small to provide useful information (Strickland and Hasson, 1993).

Two large RCTs and 11 nonrandomized controlled studies suggest that the duration of weaning can be decreased by putting the direction of the wean in the hands of respiratory therapists and nurses who are guided by a protocol. If this is so, one might expect benefits in other important outcomes: reduced stay in the ICU and in the hospital and consequent reduction in costs. Inferences about the effect of these protocolized interventions on these outcomes are not strong, given the imprecision of these estimates.

Large effects were seen in the RCT (Ely, Baker, Dunagan, et al., 1996) in which patients required longer periods of ventilation. In the randomized trial in which patients required shorter periods of ventilation (Kollef, Shapiro, Silver, et al., 1997), benefits appeared larger in the patients within the study who required longer periods of ventilation. Thus, benefits of protocol-driven weaning are likely to be greatest in patients destined to spend longer periods on the ventilator.

Even if protocol-directed weaning has a favorable effect on duration of ICU stay, the generalizability of these findings is not likely universal; protocol-directed weaning may be superior in some circumstances for some patients, but probably not for all protocols and all physicians in all settings.

### Future Research

The two large studies suggest great promise for improving the care of ventilated patients through protocol-driven weaning relying on respiratory therapists and nurses (Ely, Baker, Dunagan, et al., 1996; Kollef, Shapiro, Silver, et al., 1997). A large number of important questions should provide an important focus of research in this area. To what extent do the results of these trials apply to different patients cared for by different types of physicians working in different organizational structures? Do some protocols perform better than others? For protocols and ICUs that do show a reduction in weaning time, what is the magnitude of the associated reduction in ICU and hospital length of stay, if any? How large are the associated cost reductions, if any?

## Controlled Trials of Early Versus Late Extubation Following Cardiac Surgery

These randomized trials were consistently limited by failure to do an intention-to-treat analysis, a potentially serious problem. Even considering this limitation, they unequivocally demonstrate that extubation can be achieved a few hours earlier than was the case with previous conventional practice and that this reduction likely leads to patients spending fewer hours in the ICU, and possibly less time in hospital. Significant morbidity occurs infrequently enough that CIs around relative risks with early versus late extubation are very wide. In fact, the CIs are so wide that they are consistent both with a substantial increase or a substantial decrease in relative risk with early extubation. Another way to look at this result, however, is that event rates remain low in patients receiving early extubation. These low event rates, and the safety of early extubation, may well be restricted to relatively low risk CABG patients. Results of nonrandomized controlled trials corroborated these findings.

### Future Research

Lower doses of sedation and anesthesia, early reversal of neuromuscular blockade, and early attempts to discontinue mechanical support all can reduce the duration of mechanical ventilation in patients undergoing cardiac surgery. It is likely that this will reduce the duration of stay in the ICU, but the reduction will likely be less than one day, and possibly less than one-half of one day. Although research has not established the safety of early extubation, serious event rates are so low that a trial of thousands of patients (or, even with a combined endpoint, at least many hundreds of patients) would be required to definitively establish the effect of the alternative strategies. Unless clinicians still have a high likelihood that small but important increases in morbidity follow from early extubation, there may be better use of scarce research resources than further addressing this question.

## Controlled Trials of Corticosteroids to Prevent Postextubation Airway Complications

Two well-designed trials of dexamethasone in which patients, caregivers, and those assessing outcome were blind to allocation have unequivocally demonstrated that steroids reduce postextubation stridor (Anene, Meert, Uy, et al., 1996; Telez, Galvis, Storgion, et al., 1991). In contrast to the effect on stridor, the effect on reintubation is far from clear. In one of the two studies, 7 of 32 patients not receiving steroids required reintubation in contrast to 0 of 31 receiving steroids. The trend in the other study was in the opposite direction, with 4 of 77 and 9 of 76 children requiring reintubation. We found no adequate explanation for this difference.

The four trials of steroids in adults observed so few events that even the results of the pooled analysis are essentially uninformative (Chaney, Nikolov, Blakeman, et al., 1998; Darmon, Rauss, Dreyfuss, et al., 1992; Gaussorgues, Boyer, Piperno, et al.,1987; Ho, Harn, Lien, et al., 1996): they are consistent with a reduction in relative risk of reintubation of 86 percent and also with an increase in relative risk of reintubation of 58 percent.

### Future Research

For clinicians who believe that preventing stridor in children postextubation is in itself important, the results of two randomized trials provide a definitive answer: steroids reduce the relative risk of stridor by over 40 percent. Even using the more conservative estimate of stridor frequency in patients not given steroids of 21 percent, the results suggest that one needs to treat no more 12 children with dexamethasone to prevent one from developing stridor.

For those who believe that dexamethasone is warranted only if it prevents reintubation, the question remains unanswered. Both trials found reintubation rates of over 10 percent. Although hundreds of patients would ultimately have to be enrolled in randomized trials to answer the question, it may well be worth investing the resources to resolve the issue.

In adults, the situation is different. Reinbutation for upper airway obstruction is very infrequent. Tens of thousands of patients would have to be randomized to detect the small absolute differences in effect that are the greatest one could expect even if steroids substantially reduce the relative risk of laryngeal edema. Such a trial is almost certainly not worth the resources required.

## Controlled Trials of Enteral Nutrition

Two randomized trials of high fat, low carbohydrate enteral nutrition enrolled a total of 52 patients. One study (al Saady, Blackmore, and Bennett, 1989) found a significant decrease in PaCO_2_ whereas the other (van den Berg, Bogaard, and Hop, 1994) found a significantly lower respiratory quotient and minute ventilation in patients receiving the high fat feeds. The time from feeding commencement to successful weaning was significantly shorter in the high fat group than in the isocaloric feeding group (al Saady, Blackmore, and Bennett, 1989), but in the unblinded study (van den Berg, Bogaard, and Hop, 1994), the rate of successful 3-hour spontaneous breathing trials was the same. High fat feeds appear to have favorable physiologic effects on carbon dioxide production and may be useful in patients with impaired ventilatory reserve. These two studies were underpowered for clinically important outcomes, and their results require confirmation or refutation.

### Future Research

Future RCTs in this area should enroll large numbers of difficult-to-wean COPD patients and measure clinically important outcomes such as duration of mechanical ventilation. More important questions might address weaning success based on total caloric intake rather than the composition of the feed and issues such as who should receive feeds, when, and how much should they receive.

## Controlled Trials: Miscellaneous Studies

In terms of pharmacologic interventions, the ventilation and weaning outcomes were similar in the small double-blind trial of 12 days of recombinant growth hormone (Pichard, Kyle, Chevrolet, et al., 1996). Future research with this agent is unlikely given the recent multicenter RCT showing increased mortality in ICU patients receiving growth hormone (Takala J, Ruokonen E, Webster N, et al., 1999).

In terms of technologic interventions, in the randomized trial of oximetry and capnography to monitor patients during weaning (Niehoff, DelGuercio, LaMorte, et al., 1988), approximately one-half as many blood gases were performed compared with the number in the control arm. However, the control patients were already getting approximately one blood gas every 2 hours; such a dramatic benefit is unlikely today, since this baseline blood gas frequency is highly atypical except for very difficult to wean patients.

Intensive biofeedback intervention (Holliday and Hyers, 1990) showed a dramatic difference of 12 days in duration of ventilation; however, the weaning methods were not described in this unblinded study and this estimate of the treatment effect could be inflated. This intervention is unlikely to be used in practice; perhaps a simpler version will be tested in future trials, since the principle of positive reinforcement and feedback has been shown to be effective for other health outcomes.

In terms of postextubation interventions, following CABG, three strategies were tested: NPPV, CPAP, or chest physiotherapy (Gust, Gottschalk, Schmidt, et al., 1996). All three groups had an increase in PBVI over time but PBVI was lower in the NPPV group after 30 minutes and EVLW was higher following extubation in the chest physiotherapy group. All patients sustained successful extubation. These outcomes tell us useful information about physiologic responses postextubation that can be considered in patients with high fillings pressures.

## Observational Studies Addressing Prediction of Successful Weaning and Duration of Ventilation

Investigators have assessed an extraordinarily diverse collection of potential predictors of successful weaning and duration of mechanical ventilation; we found 462 predictors. However, the results lead to a number of clear conclusions.

First, a large number of predictors are of no use in predicting the results of weaning. We found only 23 predictors that had been studied in more than 50 patients and for which investigators presented data that allowed estimates of the predictive power of the variables under study and that, at least in some studies, had appreciable predictive power (Evidence Table 14).

For another 18 predictors, investigators show results that suggest that the predictor variable was statistically significantly associated with the weaning outcome of interest but do not provide information that allows us to estimate the predictive power (Evidence Table 14). When this information is lacking, it is not possible to use information from the predictor is a useful way in clinical practice.

For another 25 predictors, investigators have not only provided data suggesting the variable is associated with weaning outcomes but, as in variables in Evidence Table 14, given an indication of the magnitude of predictive power. However, these variables have been studied in 50 patients or fewers, permitting only the weakest of inferences regarding their usefulness in clinical practice (Evidence Table 14).

In considering the clinical application of these results we will therefore focus on the variables whose results are summarized in Evidence Table 14. Evidence Table 14 presents two sorts of data: differences in means between patients whose weaning was successful vs. those that were unsuccessful, and sensitivities and specificities. The latter are easier to interpret.

When interpreting sensitivity and specificity, we chose to classify a test result as positive if it increased the likelihood of successful wean (sensitivity is therefore the proportion of patients with a successful wean who have a positive test result) and negative if it decreased the likelihood of a successful wean (specificity is then the proportion of patients whose wean failed who had a negative test result). The most striking finding from Evidence Table 14 is that even of these strongest predictors, none is extremely powerful. However, Evidence Table 14 shows several variables with both sensitivity and specificity above 50 percent, such as respiratory rate, tidal volume, rapid shallow breathing index, occlusion pressure, daily screening test, and successful 2-hour T-piece trial. However, it is important to note that for most of the former variables, the results are not consistent across studies. The observation that daily screening tests are predictive of successful extubation and that 2-hour T-piece trials are protective of successful discontinuation assessment supports the RCT findings suggesting that these approaches lead to more rapid weaning from mechanical ventilation.

A second important observation of the results in Evidence Table 14 is that although we frequently observe high sensitivities, not infrequently over 90 percent, we seldom see high specificities. In fact, specificities are usually well under 50 percent. This means that a positive test result increases the likelihood of success very little, whereas a negative test result may decrease the probability of success appreciably.

For the most important predictors, those for which we have similarly presented results across a number of trials, we have summarized the pooled results in Evidence Table 15. Although we have presented the odds ratios, the sensitivities and specificities, and the likelihood ratios, we think the last of these is most helpful in clinical practice and will focus on these results. (An LR of 1 means the posttest probability is the same as the pretest probability, and thus the test result is altogether unhelpful. Values of 1 to 2 (which raise probability as much as values of 1 to 0.5 lower the probability) change probability very little; values of 2 to 5 or 0.5 to 0.2 lead to small but potentially important changes in probability, values of 5 to 10 or 0.2 to 0.1 lead to moderate changes in probability, and values of greater than 10 to lower than 0.1 lead to large changes in probability.

Twice in Evidence Table 15 we see an LR of greater than 10 or lower than 0.1. The CROP index was highly predictive of successful extubation in one study (LR 19.7). P_0.1_/MIP was highly predictive of discontinuation assessment and extubation in two studies (LR 10.3 and 25.3). Although these are promising predictors, most of the remaining tests cannot provide results that are very helpful in increasing or decreasing the probability of success. We never see LRs between 5 and 10, and very seldom do we see values of lower than 0.2. One study, however, found that the rapid shallow breathing index had a LR of 4.7 associated with successful extubation. Nevertheless, on balance, the best we can hope for with any of these tests is moderate changes in probability of successful weaning. Some tests are only slightly helpful, with LRs associated with positive results lower than 2 and LRs associated with negative results no lower than 0.5. Considering the pooled data, several predictors are nonetheless significant. These include tidal volume, rapid shallow breathing index, and NIF in predicting successful discontinuation assessment. Other examples are respiratory rate, tidal volume, rapid shallow breathing index, and P_0.1_/MIP for predicting extubation success. Similarly, respiratory rate, tidal volume, rapid shallow breathing index, and P_0.1_/MIP are significant predictors of successful discontinuation assessment and extubation.

The next important observation corresponds to the finding that specificities are seldom over 50 percent. LRs of positive tests are most frequently close to 1. Thus, a positive result does virtually nothing to increase the probability of success.

A negative result sometimes leads to appreciable decreases in the probability of successful wean. In interpreting these results, we will assume a pretest probability of success of 50 percent. A high respiratory rate (LR 0.32) will decrease the probability of success in reducing mechanical support from 50 percent to approximately 25 percent, the probability of success in a trial of unassisted breathing (LR 0.25) to approximately 20 percent, and the probability of success in a trial of extubation (LR about 0.5) to approximately 33 percent.

The most frequently studied and one of the most powerful tests is the rapid shallow breathing index. Pooled results for this test consistently show that a positive result (breathing pattern is neither rapid nor shallow) is moderately helpful in increasing the probability of a successful wean: individual study LRs are usually lower than 2, meaning the pretest probability of 50 percent will rise no higher than 66 percent. A negative result (breathing tends to be rapid and shallow) decreases the probability of a successful weaning trial alone or in combination with extubation from 50 percent to about 17 percent. Considering pooled data, the LR for the rapid shallow breathing index at predicting successful discontinuation assessment was 1.7, at predicting successful extubation was between 1.3 and 1.8 (the latter occurs when the variable is indexed to body weight), and at predicting successful discontinuation assessment and extubation was as high as 2.8. The power of the rapid shallow breathing index for the outcome of successful extubation alone is moderate (LR of approximately 0.4 corresponding to a change in probability from 50 percent to about 30 percent).

Why do these tests perform so poorly? The likely explanation is that physicians have already considered the results when they choose patients for trials of weaning. For instance, clinicians may seldom test patients with very high respiratory rates, who are capable of generating only very low pressures, or whose tidal volumes are very low for their ability to wean. Similarly, clinicians may not wait until the respiratory rate, tidal volume, or pressure generation is normal before they wean, for this would lead to excessive time on the ventilator. This means that the range of results in patients who are tested is relatively narrow.

Furthermore, when results of a single test are more extreme, it is likely that physicians are attempting a wean only because other observations suggest the limited impact of an isolated aberrant finding. For instance, adequate tidal volume and pressure generation may indicate to a clinician that an elevated respiratory rate is due largely to patient anxiety and does not indicate that the patient will be unable to wean. These considerations suggest that it is unrealistic to expect physiologic tests to be highly predictive in patients who clinicians judge have an intermediate probability of weaning success.

### Future Research

Investigators who continue to work in this area should present their results in a manner that allows easy clinical interpretation. Likelihood ratios provide the best format; sensitivity and specificity provide common, but less easily applied, measures of predictive power. Presenting only means and measures of variance for successful and unsuccessful groups, or regression coefficients and p values, is far less useful.

Investigators would ideally not use a single cutpoint but present multiple cutpoints. For instance, rather than reporting success rates in patients with respiratory rates above and below 36, investigators should report success rates in patients with respiratory rates lower than 20, 21 to 28, 29 to 36, 36 to 44, and greater than 44. These cuts are obviously arbitrary. The point is that since extreme results may be highly predictive, intermediate results intermediately predictive, and results at the margin not predictive at all. Use of a single cutpoint or threshold obscures this important information.

Having said this, investigators and clinicians should not expect any test to be particularly powerful. Findings to date validate clinical intuition: once clinicians have decided that a patient is likely but not certain to wean, formal examination of physiologic tests that the clinician has in some way considered in making the decision about pretest probability is unlikely to be very helpful. This suggests that randomized trials of protocol versus clinician-directed weaning are much more likely to improve the care of ventilated patients undergoing weaning than further attempts to improve clinical prediction.

## Observational Studies Describing Patient Experience During Weaning

Patients in the ICU can have a range of difficult experiences. These may be particularly acute when they are moving toward liberation from mechanical ventilation. In two of these studies (Bouley, Froman, and Shah, 1992; Lowry and Anderson, 1993), data were collected while patients were ventilated. These studies are limited by small sample sizes. Some of the studies provide details of the properties of the instruments they used whereas some studies used simple visual analog scales. Dyspnea was not found to be subjectively different across different modes of weaning. Lack of mastery, hopelessness and fear were found in one study (Lowry and Anderson, 1993) while another found depression, anxiety, fear of abandonment by staff (Pochard, Lanore, Bellivier, et al., 1995) and fear of inability to speak (Menzel, 1997). Stronger research methods would be welcome in this field, including explicit assessments of competency, reporting of cognitive status and recording recent drug exposure in patients. Some of these studies were very rigorous in reporting the properties of the instruments they used; validity and reliability in future studies should ideally be determined in the same population of patients as the ones under study. Awareness of these adverse experiences is important for all clinicians, and provision of support to attend to them is part of holistic critical care.

## Strengths and Limitations of This Review

The limitations of any review can be categorized into those relating to the review methods themselves and those related to the primary studies included in the review. We addressed strengths and limitations of the primary studies (randomized trials, nonrandomized controlled trials, observational studies and qualitative studies) in previous sections of this report. We will now critically appraise this report according to the review methodology we employed.

### Did the Review Address a Focused Clinical Question?

We were provided five specific questions by AHRQ that focused our literature review. The latter three questions-(3) What are the most effective methods of weaning from mechanical ventilation? (4) What are the optimal roles of nonphysician health care professionals in facilitating safe and expeditious weaning? and (5) What is the value of clinical practice algorithms and computers in expediting weaning?-were answered more easily by randomized or nonrandomized controlled trials, since they implicitly address interventions. The first two AHRQ questions-(1) When should weaning be initiated? and (2) What criteria should be used to initiate the weaning process?-implicitly address predictors of weaning readiness and predictors of successful liberation from mechanical ventilation. Our task was not to summarize cardiorespiratory physiology or the important experiments in respiratory mechanics that have led to our current understanding of the process of weaning from mechanical ventilation. These provide the foundation for interpreting all data contained within this report. Our task was to address the evidence related directly to the relative impact of different approaches to weaning on patient-important outcomes.

### Were the Criteria Used to Select Studies for Inclusion Appropriate?

We answer this question by considering: (1) the design and publication type of included studies, (2) the population and setting of interest, (3) the interventions evaluated, and (4) the outcomes measured. (1) We included randomized trials, nonrandomized controlled trials, observational studies, and reports of qualitative research. We excluded editorials, letters, consensus conference reports, and position papers that contained individual and collective wisdom on the topic of weaning from mechanical ventilation but did not contain original research results. (2) We included relevant adult and pediatric literature but excluded research on neonates and populations with highly specific diagnoses (Guillain-Barré syndrome and flail chest). Our report does not incorporate research on patients receiving home ventilation. (3) We focused on interventions designed to aid weaning from mechanical ventilation; we excluded other interventions that might influence duration of ventilation such as anesthetic techniques, neuromuscular blockers, fluid administration, lung protective ventilation strategies, and other interventions initiated at the onset of mechanical ventilation. Some interventions in this category such as anesthetic techniques and neuromuscular blockers were considered if they were part of a complex intervention designed to hasten extubation (e.g., as part of an approach to facilitate early extubation in postcardiac surgery patients). (4) Finally, we excluded studies that only examined physiologic endpoints, given the AHRQ questions.

### Is It Likely That Important, Relevant Studies Were Missed?

The scope of our searching was broad, and involved five large databases (MEDLINE, CINAHL, HealthSTAR, EMBASE, and the Cochrane Library). Use of EMBASE maximized the possibility of identifying relevant European literature to avoid a language bias in this review, and we included French, Italian, Spanish, Japanese, and Russian studies. Searching EMBASE, HealthSTAR and CINAHL maximized the chances of finding relevant studies in nursing and respiratory therapy journals to avoid a biased selection of research in medical journals. We also hand searched Respiratory Care; even though this journal is indexed on CINAHL, we have previously found that many research reports are poorly indexed in bibliographic databases. We used the most current randomized trial registry from the Cochrane Library, as well as citation review, our personal files, and author contact. Thus, our searching strategy was comprehensive and minimized language bias and discipline bias. Although we consulted a library scientist for our search strategy and did some hand searching, it is possible that some relevant studies are not included in this report. Three important PhD nursing theses fall into this category and are listed in the bibliography; we have carefully recorded articles that we excluded or considered and excluded in the bibliography. We omitted studies addressing the reproducibility of predictors (and also only considered one value of each predictor in studies that measured predictors over time). Although studies evaluating the reproducibility of these predictors are important, they did not directly address the five AHRQ questions.

### Was the Validity of the Included Studies Appraised?

We critiqued each study in this report, providing clinical characteristics and methodologic details in the text and associated tables. Given the diversity of the objectives, designs, populations, interventions, predictors, and outcomes of these studies, we did not use a universal quantitative scoring system to assess validity but chose instead a more explicit component approach to quality assessment, adapted to each research question and study design. We used critical appraisal questions for most studies taken from the Users' Guides to the Medical Literature (Jaeschke, Guyatt, and Sackett, 1994a, 1994b) series published in the Journal of the American Medical Association, including one manuscript in progress for the qualitative studies.

### Were the Assessments of Studies Reproducible?

Because reviews are retrospective exercises and prone to systematic and random error, we conducted several steps in this systematic review in duplicate, including: (1) citation review from the bibliographic databases, (2) assessment of relevance based on the full text of each paper, (3) assessment of methodologic quality, (4) abstraction of clinical characteristics and results, and (5) statistical analysis. Steps 3 and 4 involved critical care fellows and respiratory therapists trained in research methods. Our core research team members interpreted and synthesized the findings in dupulicate. We were as careful as possible conducting the review but identified and remediated errors at each step in our process.

### Were Results Similar From Study to Study?

The issue of heterogeneity is important for this review. In the text and tables, we show the diverse questions, designs, populations, interventions, predictors, and outcomes incorporated in these studies. These are issues of clinical heterogeneity. We only pooled data from a small proportion of the randomized trials and observational studies when clinically and statistically sensible. We did not pool results across study designs (e.g. randomized trials and nonrandomized controlled trials) and have explained our methods and rationale in the body of this report. We measured statistical heterogeneity of study results using a formal test and report and interpret this where relevant.

## Summary of Inferences From This Review

- Differences in clinicians' intuitive threshold for reduction or discontinuation of ventilatory support have a far greater impact on failure of spontaneous breathing trials, or on reintubation, than do modes of weaning. When clinicians set a high threshold, many patients who could tolerate weaning remain on mechanical support longer than is necessary.
- There may be an interaction between threshold and mode of weaning; that is, one mode may be superior when the threshold is high and another when the threshold is low.
- IMV may be less advantageous than other modes of reducing support.
- The issue of the optimal start of weaning is confounded by alternative definitions of weaning: one reasonable conceptualization is that weaning begins with the onset of mechanical ventilation. Research to date suggests the best answer to "when to start weaning" is to develop a protocol implemented by nurses and respiratory therapists that begins testing for the opportunity to reduce support very soon after intubation and reduces support at every opportunity.
- Failure of extubation is to an extent a surrogate outcome for the putative adverse consequences of failure to extubate: prolonged ventilation, oropharyngeal or gastric aspiration, acute lung injury, and cardiovascular compromise. Prolonged ventilation prior to extubation may also increase the likelihood of each of the measurable endpoints that flow from these processes: pneumonia, myocardial infarction, and death. Most trials to date are not powered to examine the frequency of these events and can thus provide little information on the tradeoff between reducing the length of ventilation prior to extubation and decreasing the rate of reintubation.
- The most promising mode of ventilatory support is NPPV, which may shorten the duration of ventilation, avoid reintubation, and reduce mortality.
- In low-risk cardiac patients, strategies to shorten duration of ventilation through early extubation can be successfully implemented while maintaining very low complication rates.
- Although steroids can reduce postextubation stridor in children, their impact on reintubation in children and adults remains uncertain.
- Most theoretically plausible predictors of weaning and extubation success have no predictive power, and even those with some predictive power are relatively weak. Tests are rarely useful in increasing the probability of success; on occasion, they can lead to moderate reductions in the probability of success.

We can reframe these conclusions in terms of the original AHRQ questions as follows:

1. When should weaning be initiated?

2. What criteria should be used to initiate the weaning process?

Explicit protocols that begin testing for the opportunity to reduce support very soon after intubation and reduce support at every opportunity have consistently done as well or better than intuitive approaches when formally tested in appropriate patients. Details of these protocols differ; any provides reasonable guidance.

3. What are the most effective methods of weaning from mechanical ventilation?

For most methods of weaning, the impact may be small in relation to criteria used for the reduction and discontinuation of support. The use of NPPV may be an exception.

4. What are the optimal roles of nonphysician health care professionals in facilitating safe and expeditious weaning?

Weaning protocols implemented by respiratory therapists and nurses are likely to reduce the duration of mechanical ventilation and may reduce length of ICU stay, and thus health care resource consumption.

5. What is the value of clinical practice algorithms and computers in expediting weaning?

Computer algorithms have received minimal study and have attendant logistic barriers; they have not been compared with weaning protocols.

## Summary of Recommendations for Future Research

Examination of alternative weaning strategies should enroll homogeneous patient groups: those whose likely period of additional ventilation is a few hours, and those whose likely period is a few days. Patients after cardiac surgery constitute another relevant patient population that should be considered separately. In this group, the success of strategies to decrease ventilation time in low risk patients can be considered established.

In the setting of a high threshold for extubation associated with low failure rates, investigators would require trials of thousands of patients to demonstrate differences between techniques and tens of thousands to demonstrate differences in complications of failed extubation. Investigators should establish plausible event rates before embarking on clinical trials.

Investigators should attempt to elucidate the tradeoff between decreasing duration of time on a ventilator and the increase in reintubation rates associated with a low weaning threshold (e.g., what reduction in duration of time on a ventilator would warrant an increase in reintubation rates from 5 to 10 percent)? This work should consider the important consequences of prolonged ventilation or reintubation, including nosocomial pneumonia, cardiac morbidity, and death.

Investigators should launch trials examining the use of NPPV in reducing the duration of intubation and total mechanical support. Future research should also explore the optimal target population, timing and management of NPPV for weaning purposes, its effect on morbidity, length of ICU stay, and mortality.

Investigators should launch randomized trials of weaning protocols implemented by respiratory therapists and nurses. These trials should evaluate the differential impact of protocols in different types of patients and in ICUs with different organizational structures (e.g., openversus closed units, teaching versus community hospitals). The influence of different protocols and their impact on ICU and hospital length of stay and costs are important future considerations.

A more fruitful line of investigation than further research seeking powerful predictors of successful weaning or extubation might be randomized trials of weaning protocols that decrease the duration of mechanical ventilation without substantially increasing rates of failed extubation.