# Results

Our database search for relevant articles yielded a total of 5,653 citations of which 927 proved potentially eligible on the basis of reviewing the title and abstract. We were able to obtain hard copies of 924 of these articles. We included a total of 154 studies after comprehensive review of the full article. The absolute agreement between the two observers for determining eligibility for articles was 0.89 and the kappa for agreement was 0.68.

Evidence Tables 1 to 4 summarize the general characteristics of the 154 articles included in this systematic review. (Duplicate publications have not been represented twice; therefore, most items in these tables sum to reflect 150 studies.) MEDLINE identified most of the studies we have included, the majority of which were published after 1991 in English. Most studies failed to report sources of funding. The first three AHRQ questions are well represented, but a smaller number of studies addressed the value of practice algorithms or the optimal role of nonphysician health care providers. The investigations were generally undertaken as single center studies in adult medical or surgical ICUs serving heterogeneous populations in U.S. tertiary care hospitals.

We will now describe in sequence the results of the categories of studies we have addressed: randomized controlled trials, non-randomized controlled trials, observational studies examining predictors of weaning success and duration, qualitative studies, and quantitative studies of patient experience.

## Randomized and Nonrandomized Controlled Trials

We identified 46 randomized trials from which we abstracted data. All were English except one, which was published in French. Evidence Table 5 summarizes the methodologic characteristics of the studies. Over one-half did not describe the method of randomization, and most did not address issues of concealment and were unblinded.

We identified an additional 25 nonrandomized controlled trials in 23 unique publications, the methodologic characteristics of which are presented in Evidence Table 9. All were English language publications except one, which was Japanese. Most were retrospective reviews of patient outcomes before and after the implementation of managed approaches to weaning interventions. Many of these studies were characterized by common limitations of observational studies: dissimilar use of cointerventions between experimental and control groups and a lack of explicit definitions of study measurements (in this case, weaning criteria and extubation criteria).

Evidence Table 5 also presents a classification of the randomized trials we have included. (We use the same classification for nonrandomized controlled trials.) In the first clinical context we identified, the clinician believes the patient is likely to tolerate a test of spontaneous breathing (usually implying extubation) but has some uncertainty. The clinician has a variety of modes of ventilation available to test the patient's ability to tolerate unassisted breathing. We refer to this group of studies as "studies comparing alternative discontinuation assessment strategies."

In the second clinical context we identified, the clinician faces a patient who is improving but who is unlikely to tolerate unassisted ventilation for at least 24 hours and perhaps up to several days. The clinician wishes to progressively decrease the level of mechanical support and has a number of modes available to achieve this goal. We refer to this group of trials as "studies comparing alternative ventilation modes for stepwise reductions in mechanical support."

We identified three studies that addressed related issues but did not fit clearly into either one of these categories. These studies examined the impact of stepwise reductions in mechanical support in patients over periods of up to 48 hours.

We identified three RCTs that compared physician-directed weaning with weaning directed by a protocol with major involvement from respiratory therapists and nurses or a computer-driven protocol.

Another set of randomized trials dealt with the timing of extubation in patients who had undergone cardiac surgery. The management issue is whether clinicians can achieve early extubation without deleterious consequences for patients. Investigators have addressed two approaches to early extubation in such patients: alternative anesthesia regimens and alternative strategies once the patient reaches the ICU.

Investigators have tested, in both children and adults, whether parenteral steroid administration could reduce postextubation edema and thus prevent stridor or distress requiring reintubation.

The balance of fat and carbohydrate that patients receive determines their respiratory quotient and the amount of carbon dioxide they produce. Theoretically, this may influence the burden on their respiratory system during the weaning process. Two RCTs have tested the hypothesis that weaning could be expedited by use of low carbohydrate feeds.

We also found a number of studies in which the interventions do not fit into any of the categories listed above. Evidence Table 5 summarizes the miscellaneous interventions tested in these studies.

Evidence Table 5 lists the outcomes measured in these RCTs. Of these outcomes, there are a number we consider much more important than the others. In general, these outcomes are those that we believe patients would consider important. They include mortality, successful spontaneous breathing trial, reintubation rate, signs of impending airway obstruction postextubation, duration of intubation and mechanical intervention, length of ICU and hospital stay, and major morbidity.

We will now summarize the results of each of the studies in each of the categories we have identified above. Relevant tables for each category of randomized studies include Evidence Table 6 that describes the characteristics of randomized trials, Evidence Table 7 that describes RCT results, and Evidence Table 8 that summarizes the results of pooling across RCTs for those groups of studies in which pooling proved appropriate. The characteristics of the nonrandomized controlled trials are found in Evidence Table 9; the results of the nonrandomized controlled trials are summarized in Evidence Table 10. These results are not included in pooled analyses.

## Controlled Trials of Discontinuation Assessment Strategies

The sample size of the eight randomized studies of discontinuation assessment strategies modes varied from 18 to 526; three of the studies enrolled more than 100 patients (Evidence Table 6). The largest studies (Esteban, Alia, Gordo, et al., 1997; Esteban, Alia, Tobin, et al, 1999) were methodologically strong, reporting the method of randomization and weaning, extubation, and reintubation criteria. Lack of concealment of randomization could easily bias the results of these studies, and although none of the studies used the optimal method of ensuring concealment (randomization by an independent methods center), the Esteban studies used the next best approach for a study such as this-opaque sealed envelopes. Other randomized trials were methodologically not as strong (Evidence Table 6).

The first Esteban study (Esteban, Alia, Gordo, et al., 1997) compared 2-hour trials of unassisted breathing using pressure support of 7 cm H_2_O versus a T-piece trial. A smaller proportion of those in the pressure support group, 14 percent, failed to tolerate the wean and achieve extubation at the end of the 2-hour trial than in the T-piece group, 22 percent (relative risk 0.64, 95 percent CI 0.43 to 0.94) (Evidence Table 7). Of those extubated, 38 patients in the pressure support group and 36 in the T-piece group required reintubation (Evidence Table 7).

The second Esteban study (Esteban, Alia, Tobin, et al., 1999) compared a 30-minute with a 120-minute T-piece trial of spontaneous breathing prior to extubation. There was no reported difference in the rate of reintubation between groups, and patients randomized to the shorter T-piece trial benefited from statistically significant reductions in ICU and hospital length of stay (2 days and 5 days shorter, respectively).

The other randomized studies, all of which compared T-piece trials with alternative strategies usually including some form of pressure support, had much smaller sample sizes and generally had lower event rates. Our judgment was that we could pool only across two trials that compared T-piece to CPAP and even after pooling, the number of events is so low that the 95 percent CIs are extremely wide: relative risk for nonextubation in CPAP versus T-piece 1.66 (95 percent CI 0.60 to 4.64); relative risk for reintubation 1.61 (95 percent CI 0.39 to 6.59) (Evidence Table 8).

There were no nonrandomized trials in this category of weaning interventions.

## Controlled Trials of Progressive Reduction in Mechanical Support

Five RCTs compared alternative methods of decreasing ventilatory support in patients in whom clinicians thought that extubation was still several days away. Their sample size varied from 19 to 130; two trials enrolled more than 100 patients (Evidence Table 6). Three of the trials, including the two largest, used sealed opaque envelopes to protect concealment and described criteria for weaning and extubation. The most informative results come from the two largest studies (Brochard, Rauss, Benito, et al., 1994; Esteban, Frutos, Tobin, et al., 1995). These two studies compared three modes that were delivered in similar ways in the two studies: multiple daily T-piece, pressure support, and SIMV. The Esteban trial also included a fourth arm, once daily T-piece, which demonstrated results very similar to those from the multiple daily T-piece (Evidence Table 7).

In both studies, the investigators recruited patients who had failed a T-piece trial. Esteban, Frutos, Tobin, et al. (1995) conducted their T-piece trial in 546 patients, only 130 of whom had respiratory distress during a 2-hour T-piece trial. Brochard, Rauss, Benito, et al. (1994) found a similar strikingly high proportion of patients who tolerated their 2-hour T-piece trial: of 456 patients in who underwent the T-piece trial, only 109 were unable to tolerate spontaneous breathing and were therefore randomized.

Of those randomized, patients in the Esteban trial had a prior mean duration of mechanical ventilation of approximately 9.3 days, with a minimum of 24 hours. Brochard's patients also had a minimum duration of ventilation of 24 hours. The approximate mean duration of ventilation in the Brochard patients was 14 days.

Because the interventions of the two studies are reasonably similar, we pooled the results for the outcomes that were measured in similar ways (Evidence Table 8). We present two sets of Evidence Tables 8: one deals with duration of ventilation, and the other the relative risk of the combined endpoint of nonextubation in 2 to 3 weeks and the need for reintubation. In the comparison of T-piece to pressure support, the pooled results showed no difference in duration of ventilation, the trends going in opposite directions in the two studies (Evidence Table 8): The results from the Esteban, Frutos, Tobin, et al. (1995) study favored T-piece and those from the Brochard, Rauss, Benito, et al. (1994) study favored pressure support. As a result, the CI around the pooled estimates for both duration of ventilation and relative risk of nonextubation or reintubation is extremely wide.

In the comparison of T-piece with SIMV, the two trials showed similar trends in favor of T-piece in the duration of ventilation. The CI around the pooled results comes close to excluding no difference, with the magnitude of the pooled estimate being a difference of over 40 hours additional duration of ventilation in favor of the T-piece wean, or a relative risk of the combined endpoint of 1.48 in the SIMV group (Evidence Table 8).

In the comparison of pressure support to SIMV on duration of weaning, both studies found trends in favor of pressure support; the effect in the Brochard, Rauss, Benito, et al. (1994) study was much larger. The magnitude of the trend in the pooled result of duration of ventilation is over 60 hours, and the CI comes close to excluding no effect. The pooled results of pressure support versus SIMV on the combined endpoint show an extremely wide CI.

Jounieaux, Duran, and Levi-Valensi (1994) randomized 19 patients to SIMV with pressure support versus SIMV without pressure support. Neither group received CPAP. The duration of the wean was approximately 1 day shorter in the group that received pressure support, with the lower boundary of the CI being approximately 7 hours (Evidence Table 7). Two patients in the SIMV group, and none in the group that also received pressure support, required reintubation.

Two groups of investigators (Girault, Daudenthun, Chevron, et al., 1999; Nava, Ambrosino, Clini, et al., 1998) evaluated NPPV as a mode for stepwise reductions in mechanical support for patients admitted with COPD exacerbation who had failed a 2-hour T-piece trial. The control strategies in the two studies included pressure support ventilation, with or without CPAP. In the larger study, Nava, Ambrosino, Clini, et al. (1998) found a reduction in duration of mechanical ventilation associated with a reduction in ICU stay of almost 9 days associated with NPPV (Evidence Table 7). When the results of these studies were pooled, the reduction in ICU length of stay was 5 days (95 percent CI -12.2 days to +1.9 days) (Evidence Table 8). Pooling also indicated favorable trends in mortality (relative risk 0.30, 95 percent CI 0.09 to 1.02) and in the incidence of nosocomial pneumonia (relative risk 0.29, 95% CI 0.02 to 3.88).

Two additional nonrandomized trials evaluated the use of NPPV in weaning. Patel, Petrini, and Dwyer (1999) compared 24 hours of intermittent nasal CPAP with 24 hours of invasive CPAP in patients who were weaned for 24 hours to PS 5 cm H_2_O plus positive end-expiratory pressure (PEEP) 5 cm H_2_O following prolonged ventilation. There was a marginal increase in the reintubation rate in the patients receiving invasive CPAP versus noninvasive CPAP. Hilbert, Gruson, Portel, et al. (1998a) evaluated NPPV in COPD patients who developed hypercapnic respiratory insufficiency after extubation. Comparing patients managed with NPPV with historical controls, there was a statistically significant reduction in the rate of reintubation with NPPV and a nonsignificant survival benefit.

## Controlled Trials Comparing Alternative Ventilation Modes for Weans Lasting Less Than 48 Hours

Three randomized trials addressed an intermediate group of patients not yet ready for discontinuation assessment, but likely to be ready within 48 hours. These trials were methodologically relatively weak and included sample sizes of less than 50 patients (Evidence Table 6). Chopin, Chambrin, Mangalaboyi, et al. (1989) showed a trend in favor of CO_2_ mandatory ventilation over intermittent mandatory ventilation (IMV) and multiple daily T-piece in the proportion of patients extubated at 24 hours. However, there were only 14 patients in each of the three study groups.

The study by Esen, Denkel, Telci, et al. (1992) showed trends in favor of pressure support over IMV in both duration of ventilation and successful extubation in 48 hours (Evidence Table 7).

Davis, Potgieter, and Linton (1989) compared an IMV wean (18 patients) to a wean based on setting the mandatory minute volume (MMV) to 75 percent of the minute volume prior to beginning the wean. The MMV was achieved by decreasing the frequency and maintaining the tidal volume. Patients who weaned quickly did so in less than 5 hours in the MMV group and in over 30 hours in the IMV group (Evidence Table 7). Five patients in each group failed to wean quickly, and the authors do not tell us more about these patients.

Two nonrandomized controlled trials also examined alternative weaning modes for patients expected to wean very quickly from mechanical ventilation (Rathgeber, Schorn, Falk, et al., 1997; Tomlinson, Miller, Lorch, et al., 1989), with findings similar to those of the RCTs (Evidence Table 10). Tomlinson found no difference in the duration of mechanical ventilation or the duration of weaning in medical-surgical ICU patients weaning over a period of 2 hours to (rarely) 3 days using IMV (without CPAP) versus multiple daily T-piece trials. In contrast, Rathgeber, Schorn, Falk, et al. (1997) compared the use of (1) T-piece trials to (2) SIMV or (3) invasive biphasic positive airway pressure (BiPAP) weans in 586 patients following cardiac surgery. The methods in this large study were relatively strong. The results of this study were consistent with the results of related RCTs discussed above, suggesting superiority of BiPAP (CPAP plus pressure support) over T-piece weans and both modes over SIMV weans with respect to the duration of mechanical ventilation.

## Controlled Trials Comparing Weaning Protocols to Physician-Directed Weaning

Three RCTs have compared protocolized to conventional weans. One very small trial (15 patients) compared a computer-directed wean with a physician-directed wean and found trends in favor of the computer-directed wean in both nonextubation and reintubation rates (Strickland and Hasson, 1993) (Evidence Table 7).

Two RCTs compared weaning protocols that were largely implemented by respiratory therapists and nurses with conventional physician-directed weaning (Ely, Baker, Dunagan, et al., 1996; Kolef, Shapiro, Silver, et al., 1997). These trials were both methodologically strong (Evidence Table 6) and, for this area of investigation, very large (300 and 357 patients). Both studies enrolled virtually all the patients in their units receiving mechanical ventilation during the study periods.

Ely, Baker, Dunagan, et al. (1996) studied a different group of patients: median durations of mechanical ventilation were 4.5 and 6 days in the protocol- and physician-directed groups respectively. The relative risk of successful extubation in the protocol-directed group was 2.13 (95 percent CI 1.55 to 2.92, p<0.001), indicating that mechanical ventilation was discontinued sooner than in the control group. The largest separation between groups was at approximately 5 days and differences disappeared by about 15 days. Patients in the physician-directed group spent a day longer in the intensive care unit and 1.5 days longer in the hospital; neither of these differences reached statistical significance.

Kollef, Shapiro, Silver, et al. (1997) conducted their study in four intensive care units using three different weaning protocols that had been developed and tested by the ICU staff prior to the start of the study. Despite the large sample size, the power of their study to detect differences in key endpoints was limited, since most patients spent a relatively short period of time on the ventilator. In the protocol- and physician-directed groups, respectively, 25 percent of the patients were extubated by 15 and 21 hours, 50 percent by 35 and 44 hours, and 75 percent by 114 and 209 hours. Only 12% and 17%, respectively, of the patients spent more than 7 days on the ventilator. The authors used a number of sophisticated statistical survival and regression analyses that favored the intervention group and showed borderline statistical significance. More simple tests also favored the protocol-directed group, but failed to reach statistical significance (Evidence Table 7).

In addition to these RCTs, 11 nonrandomized controlled clinical trials have examined the impact of, largely, respiratory therapist- or nursing-directed weans, compared with physician-directed weans, on weaning outcomes in critically ill patients (Evidence Tables 9 and 10). These studies, conducted in a variety of patient populations, are generally much larger than the corresponding RCTs but are more prone to biased results (Evidence Table 9d). Their results are generally consistent with the results of the RCTs, demonstrating statistically significant reductions (Foster, Conway, Pamulkov, et al., 1984; Horst, Mouro, Hall, et al., 1998; Rotello, Warren, Jastremski, et al., 1992) or trends toward reductions (Burns, Marshall, Burns, et al., 1998; Kollef, Horst, Prang, et al., 1998; Saura, Blanch, Mestre, et al., 1996a; Wood, MacLeod, and Moffatt, 1995) in the duration of mechanical ventilation and ICU length of stay, as well as benefits to protocolized weans with respect to a variety of other study outcomes (number of arterial blood gases required). Mortality and reintubation rates did not appear to differ between experimental and control groups among these nonrandomized studies, nor were other complications associated with protocolized weaning reported.

## Controlled Trials of Early Versus Late Extubation Following Cardiac Surgery

Investigators have tested two types of interventions to try to reduce the duration of mechanical ventilation following cardiac surgery. One strategy involves modification of anesthesia, in particular reduction in fentanyl dose or substitution of fentanyl for propofol, and the other involves different approaches to care once patients reach the ICU. In addition to the methodologic limitations of randomized trials shown in Evidence Table 6, in particular the consistent lack of information concerning concealment, these studies failed to conduct intention-to-treat analyses. Some restricted their analysis to patients who achieved early extubation or to the extubation goals of the study arm to which the patients were allocated. We have chosen to report only outcomes in which at least 80 percent of the randomized patients in both groups are included in the analysis.

Four RCTs that tested lower doses of fentanyl in patients after coronary artery bypass surgery enrolled between 85 and 144 patients (Berry, Thomas, Mahon, et al., 1998; Cheng, Karski, Peniston, et al., 1996b; Michalopoulos, Nikolaides, Antzaka, et al., 1998; Silbert, Santamaria, O'Brien, et al., 1998) and a fifth tested fentanyl versus proprofol in 70 patients (Evidence Table 6). All five RCTs suggested a reduction in the duration of mechanical ventilation with the lower anaesthetic doses. No other outcomes consistently differed between the early and late intervention groups in the five trials (Evidence Table 7), although Cheng, Karski, Peniston, et al. (1996b) demonstrated an increase in early ischemia with a trend toward an increase in myocardial infarction.

The pooled results (Evidence Table 8) confirm a reduction in the duration of mechanical ventilation, with a mean effect of approximately 7 hours. Although there is considerable heterogeneity between studies, both the smallest mean effect seen in an individual study and the lower boundary of the CI are approximately 1 hour. The pooled results also show a difference in reduction of hospital stay of 1 day with early extubation, with a very narrow CI.

With respect to mortality and important morbidity, even after pooling across the four studies there were very few events, and as a result CIs are so wide as to be uninformative (Evidence Table 8). Except for the outcome of reintubation, what trends there were favored the early extubation strategy.

Five RCTs that used other approaches to achieve early extubation included more varied populations: one trial in elderly patients undergoing elective abdominal aortic reconstruction (Shackford, Virgilio, and Peters, 1981), one trial in patients undergoing mitral valvulotomy (Tempe, Cooper, Mohan, et al., 1995), and three trials in patients undergoing coronary artery bypass surgery (Dumas, Dupuis, Searle, et al., 1999; Quasha, Loeber, Feeley, et al., 1980; Reyes, Vega, Blancas, et al., 1997). Two RCTs reversed neuromuscular blockade to achieve early extubation (Tempe, Cooper, Mohan, et al., 1995; Quasha, Loeber, Feeley, et al., 1980); one discontinued sedation at an earlier point (Dumas, Dupuis, Searle, et al., 1999) whereas two simply instituted early efforts at extubation (Shackford, Virgilio, and Peters, 1981; Reyes, Vega, Blancas, et al., 1997). Sample sizes varied from 35 to 404; only Reyes, Vega, Blancas, et al. (1997) recruited more than 100 patients.

Results of all five trials suggested they achieved, on average, a shorter duration of ventilation in the early extubation group (Evidence Table 7). Morbid events were rare and similar in the 2 groups. The pooled analysis confirms these findings and suggests, in addition, a decrease of one-half day in ICU stay in the early extubation group (Evidence Table 8).

There are an additional eight nonrandomized controlled studies of early versus late extubation following cardiac surgery (Evidence Tables 9 and 10). These were large studies conducted primarily in adults, and all studies evaluated a combination of altered anesthetic techniques and altered ICU care to achieve early extubation. The results were very similar to the RCT results. Duration of intubation was reduced with the implementation of early extubation strategies by 1 to 28 hours, though associated reductions in ICU and hospital lengths of stay were relatively small (though inconsistent), ranging from 1 to 53 hours, and 0.3 to 2.6 days, respectively. Complication rates varied across studies in early versus late extubation groups, and these event rates were rather small.

## Controlled Trials of Corticosteroids to Prevent Post-Extubation Airway Complications

Three RCTs have addressed whether preextubation steroid administration can reduce postextubation stridor and the necessity for reintubation in children (Anene, Meert, Uy, et al., 1996; Harel, Vardi, Quigley, et al. 1997; Tellez, Galvis, Storgion, et al., 1991). In all three studies, patients, caregivers, and those assessing outcome were blind to allocation, patients having received dexamethasone or a matched placebo. Two trials (sample sizes of 66 and 153 children) enrolled patients who had not previously been extubated (Anene, Meert, Uy, et al., 1996; Tellez, Galvis, Storgion, et al., 1991). A smaller trial enrolled 23 children who had been reintubated for postextubation stridor, who received two doses of dexamethasone or placebo over 6 hours and were then extubated.

Both of the trials of primary extubation examined both stridor scores and reintubation (Evidence Table 7). Early stridor was present more frequently in both trials in the group that did not receive steroids and the differences persisted until 12 hours in the one trial that measured stridor sequentially (Anene, Meert, Uy, et al., 1996; Evidence Table 7). Reintubation occurred more frequently in the steroid group in one study (Telez, Galvis, Storgion, et al., 1991) and more frequently in the no steroid group in the other study (Anene, Meert, Uy, et al., 1996). In the trial of secondary extubation, the stridor score was slightly and not significantly greater in the no steroid group, which also had a higher incidence of reintubation (5 of 11 versus 3 of 12). This difference did not approach statistical significance.

One nonrandomized controlled study evaluated corticosteroids to prevent postextubation airway complications in children. In a study evaluating steroids in patients who had failed extubation the first time, Freezer, Butt, and Phelan (1990) reported a statistically significant reduction in prolonged reintubation (>6 days) and in failed reextubations.

The pooled analysis of the two randomized trials of primary extubation demonstrated a substantial reduction in the frequency of stridor with a relatively narrow CI (relative risk 0.57, 95 percent CI 0.40 to 0.81) (Evidence Table 8). The pooled analysis also suggested a reduction in reintubation with steroids; but partly because of the trends in different directions in the two studies, the CI is extremely wide (relative risk 0.50, 95 percent CI 0.02 to 13.87) (Evidence Table 8).

The four trials of steroids in adult patients used different medications (methylprednisolone, dexamethasone, and hydrocortisone); three (Chaney, Nikolov, Blakeman, et al., 1999; Darmon, Rauss, Dreyfuss, et al., 1992; Ho, Harn, Lien, et al., 1996) were placebo-controlled. Only one of the studies assessed post-extubation stridor (Ho, Harn, Lien, et al., 1996) and found little difference between the two groups (Evidence Table 7). The need for reintubation was very infrequent in all 4 studies. As a result, even the pooled analysis demonstrates extremely wide CIs around the pooled estimate of steroid impact on reintubation (Evidence Table 8).

## Controlled Trials of Enteral Nutrition

High carbohydrate loads can markedly increase carbon dioxide production, resulting in a respiratory quotient of >1.0. The biologic rationale for the high fat, low carbohydrate intervention tested in the following two trials is that the lower respiratory quotient might improve gas exchange and facilitate weaning from mechanical ventilation in patients with limited ventilatory reserve.

In a randomized, double-blind trial (al-Saady, Blackmore, and Bennett, 1989), 20 medical ICU patients were allocated to: (1) a high fat, low carbohydrate enteral feeding solution (Pulmocare: 17 percent protein, 55 percent fat, 28 percent carbohydrates) or (2) isocaloric feeds (Ensure Plus: 17 percent protein, 30 percent fat, 53 percent carbohydrates). Nutritional requirements were calculated at 1.5 times basal metabolic rate, delivered through a nasogastric tube. Patients were eligible if they had either COPD, asthma, pneumonia, or neurologic disease and if they could tolerate enteral nutrition. Exclusion criteria were nephrotic syndrome, hepatic failure, or diabetes mellitus. Patients were mechanically ventilated using intermittent positive pressure ventilation. Weaning was started when patients had a respiratory rate <30 breaths/minute, minute ventilation was <12 L/minute, if arterial partial pressure of oxygen (PaO_2_) at fractional inspired concentration of oxygen (FiO_2 _) was >60 mmHg, when arterial partial pressure of carbon dioxide (PaCO_2_) was 38-45 mmHg, and when pH was >7.3. T-piece weaning continued and was considered successful at 24 hours if the following were maintained: clinically and hemodynamically stable, respiratory rate <30 breaths/minute, minute ventilation <10 L/minute, if PaO_2_ at FiO_2 _was >60 mmHg, when PaCO_2_ was 38-45 mmHg, and when pH was >7.3. The study was terminated as soon as patients were able to tolerate 3 hours of spontaneous breathing.

Randomization methods and concealment of allocation were not reported. The study was doubleblinded. Patients were comparable at baseline with respect to basic demographics, and preintervention duration of ventilation (approximately 64 and 70 hours, respectively). Cointervening carbohydrate loading in intravenous dextrose or oral medication was avoided.

Only one patient developed delayed gastric emptying in the high fat group; feeds were held for 2 hours but recommenced with no further problem. The PaCO_2 _decreased significantly in the high fat feeding group just prior to weaning but increased slightly in patients receiving the isocaloric feed (p=0.003), whereas there was no difference in PaO_2_ and tidal volume or respiratory rate. The time from feeding commencement to successful weaning was significantly shorter in the high fat group than in the isocaloric feeding group (86.1±17.8 versus 148.7±36.7 hours).

In a second randomized unblinded enteral nutrition trial (van den Berg, Bogaard, and Hop, 1994), 32 medical ICU patients were allocated to: (1) a high fat, low carbohydrate enteral feeding solution (Pulmocare: 17 percent protein, 55 percent fat, 28 percent carbohydrates) or (2) isocaloric feeds (Ensure Plus: 17 percent protein, 30 percent fat, 53 percent carbohydrates). Nutritional requirements were calculated at 1.5 times basal metabolic rate, delivered through a nasogastric tube. Patients were eligible if they had either COPD, neurologic disease, or pneumonia without COPD and if they could tolerate enteral nutrition. Exclusion criteria were renal failure, hepatic failure, diabetes mellitus, or respiratory failure "without a prospect of weaning from the ventilator." Patients were mechanically ventilated with a volume controlled mode. Weaning was started using CPAP when patients were afebrile, hemodynamically stable, required PEEP <10 cm H_2_O on FiO_2_ and when serum bicarbonate was <28 mmol/L. CPAP continued for a maximum of 3 hours until patients were too dyspneic or tired too continue; specific failure criteria were not reported. Rest periods lasted 4 to 6 hours and CPAP weaning trials occurred between rest periods. The study was terminated as soon as patients were able to tolerate 3 hours of spontaneous breathing.

Randomization was stratified based on the presence or absence of COPD. Concealment and allocation methods were not reported. Adherence to the feeding regimens was successful in all but one patient in each group, whose feeding was discontinued because of gastric distension; the outcome of these patients is not reported. Patients were comparable at baseline with respect to illness severity and nutritional status. Although the stratification of randomization based on COPD resulted in similar numbers of COPD patients in each arm, the distribution of cases of acute or chronic COPD as a reason for respiratory failure was not similar. In the high fat group, 10/11 patients with COPD were ventilated for acute or chronic respiratory failure versus 5/13 in the isocaloric feeding group. The former group also had severe hypercapnia during ventilation and during the weaning process; since this imbalance affected interpretation of the trial, two-way analysis of variance was used to evaluate whether the results obtained were related to the respiratory failure rather than the nutritional intervention.

The respiratory quotient was significantly lower in patients receiving the high fat, low carbohydrate feed compared with the isocaloric feed (0.72±0.02 versus 0.86±0.02, p<0.01). The minute ventilation during weaning was also lower (8.8±0.9 versus 10.5±0.8, p<0.01). A similar proportion of patients in both arms had a successful 3-hour trial of spontaneous breathing on CPAP (12/14 versus 13/16, p=0.74).

In a related nonrandomized controlled trial, Bassili and Dietel (1981) evaluated the effect of any (enteral or parenteral) nutritional support on weaning patients from mechanical ventilation. Patients comprising the control group received intravenous D5W (glucose solution), only. Though there was no difference in duration of mechanical ventilation between the two groups, there was a very large excess of nonextubations in the control patients. Possible causes of nonextubation are not reported (e.g., death, need for permanent tracheostomy, etc.).

## Randomized Trials of Miscellaneous Studies

There are seven randomized trials grouped in this miscellaneous category. Outcomes are summarized in the Evidence Table 7 (Gust, Gottschalk, Schmidt, et al., 1996; Holliday and Hyers, 1990; Jiang, Kao, and Wang, 1999; Lee, Chien, Hsu, et al., 1998; Niehoff, DelGuercio, LaMorte, et al., 1988; Pichard, Kyle, Chevrolet, et al., 1996). An additional article did not report outcomes in a manner that allowed extraction for our purposes; therefore, it is not represented in the Evidence Table 6 or 7.

(1) The rationale for the first study (Niehoff, DelGuercio, LaMorte, et al., 1988) is that arterial blood gas analysis may not be needed as often if continuous monitoring of oxygenation and ventilation is provided during weaning. This trial was not designed to test the accuracy or utility of oximetry and capnography (which has been evaluated in technology assessment literature) but to evaluate its utility as a weaning adjunct.

In a randomized, unblinded trial, 24 postoperative cardiac patients were allocated to pulse oximetry and capnography or periodic arterial blood gases. IMV was used for weaning but stepwise decrements were not specified. The oximetry and capnography group had arterial blood gases on ICU admission, just before extubation, and if SaO_2_ <95 percent or end-tidal CO_2_ (PetCO_2_) <26 or >40 mmHg, and as clinically indicated. The blood gas group was weaned if PaCO_2_ was 35 to 45 mmHg and pH was 7.35 to 7.45, PaO_2_>70 mmHg and respiratory rate <30 breaths/minute.

There were fewer blood gases performed in the oximetry and capnography group (5.9±2.7 versus 10.1±1.8, p<0.01). The duration of ventilation was similar (18.8±2.0 versus 19.7±1.9 hours). One patient in the blood gas group did not get extubated and was excluded from analysis. No patients required reintubation.

(2) To induce anxiolysis and minimize muscle fatigue, the effect of relaxation biofeedback on respiratory mechanics and weaning was tested (Holliday and Hyers, 1990).

In an unblinded randomized trial, 40 patients ventilated for >7 days were allocated to relaxation biofeedback or a control group. The biofeedback group received a multifaceted intervention for 30 to 50 minutes per day on CPAP 5 cm H_2_O for 5 days per week until study termination, consisting of of communication (the patient was asked about feelings, breathing, and sleeping and was encouraged), tidal volume (V_t_) feedback (auditory and visual feedback on a computer screen of the patients V_t_ compared with a threshold V_t_) and computerized visual feedback of frontalis muscle tension by electromyography (EMG).

Cointerventions were not well described during the weaning process. Four patients randomized to the control group died and were not included in the analysis. Within-group changes in maximum inspiratory pressure (MIP), tidal volume, and minute ventilation were no different. The duration of ventilation was 12 days shorter in the biofeedback group (20.6±8.9 days versus 32.6±17.6 days, p=0.01). Nonextubation rates were the same. The undisclosed weaning using T-piece or IMV in this unblinded study that found a 12-day difference in duration of ventilation makes interpretation difficult; moreover, the generalizability of this technologically complex intervention is also limited.

(3) Functional residual capacity postspontaneous breathing on T-piece may be better restored with NPPV and CPAP than with spontaneous breathing and physiotherapy, thereby minimizing pulmonary edema and extubation failure.

In a randomized, unblinded trial of 75 cardiac surgery patients (Gust, Gottschalk, Schmidt, et al., 1996), three postextubation interventions were evaluated after 10 to 14 hours of controlled ventilation and 30 minutes of T-piece breathing. Patients were extubated, then randomized to either NPPV (n=25) involving BiPAP using the spontaneous timed mode (S/T) via nasal mask with an inspiratory positive airway pressure (IPAP) of 10 cm H_2_O and an expiratory positive airway pressure (EPAP) of 5 cm H_2_O and 10 L/minute of oxygen via nasal mask for 30 minutes; CPAP 7.5 cm H_2_O and FiO_2_ 0.5 for 30 minutes (n=25); or chest physiotherapy for 10 minutes and oxygen via nasal mask at 6 L/minute for 30 minutes (n=25).

Left ventricular function and inotropic support were comparable across groups. Cardiac surgical, anesthetic, and preextubation ICU management for the entire cohort are well described. No patients were lost to followup, and the analysis was intention-to-treat. All three groups had an increase in pulmonary blood volume index (PBVI) over time: 17 ml/m^2^, 9 ml/m^2^, and 17 ml/m^2^ for BiPAP, CPAP, and chest physiotherapy, respectively. Following 30 minutes of each intervention, however, PBVI in the BiPAP group was significantly lower than the other two groups (p<0.05). Extravascular lung water (EVLW) increased significantly from extubation through the 30-minute intervention to 90 minutes following extubation in the chest physiotherapy group, compared with the other two groups (p<0.05). All patients in each group had sustained extubation.

(4) The rationale for this intervention is the catabolism of critical illness and functional and structural neuromuscular abnormalities in ventilated patients. Peripheral skeletal muscle function may improve following 1 week of postoperative growth hormone; however, a recent multicenter randomized trial showed that growth hormone was associated with increased ICU mortality (Takala, Ruokonen, Webster, et al., 1999). Nevertheless, this study of 12 days of growth hormone evaluated the duration of ventilation (Pichard, Kyle, Chevrolet, et al., 1996).

In a randomized, double-blinded trial, 20 patients requiring ventilation for >7 days were allocated to either 0.43 IU of recombinant growth hormone/kg/day administered subcutaneously for 12 days or normal saline. Patients were excluded if they had known myopathy, neuropathy, or a risk factor for neuromuscular abnormalities. Weaning began for all patients when: minute ventilation <10 L/minute, vital capacity >1 L, PaO_2_>60 with FiO_2_<0.4, or if a T-piece trial was tolerated for 30 minutes. Weaning began with SIMV; PS was added when spontaneous breathing developed and was gradually lowered. At PS of 10 cm H_2_O, patients underwent a T-piece trial; after 12 hours of spontaneous breathing, patients were extubated. Parenteral nutrition was provided for the first 48 hours, and enteral nutrition was instituted.

After 12 days, the growth hormone group had higher growth hormone, insulin-like growth hormone factor-1, and insulin levels. Fat-free mass was increased in the treated compared with the untreated group. The cumulative duration of weaning over 12 days was similar (235.6±17.6 versus 245.4±14.7 hours). Patients similarly remained mechanically ventilated at 12 days (7/10 and 7/10, respectively).

(5) In 21 patients requiring ventilation for at least 3 days, SIMV was compared with pressure support for patient comfort. Patients were randomized to SIMV or PS and underwent a sequential 20 percent reduction in support at timed intervals. Then patients crossed over to the other arm after a 1- to 3-hour rest. Dyspnea and anxiety remained stable over time in each mode and were no different between groups. Of the 21 patients, 10 were weaned; the attribution of success to one or the other modes is not possible given the crossover design of the study. Potentially important cointerventions such as verbal feedback and touch are not described.

(6) Acupuncture has been found to relieve sore throats; its potential benefit averting largyngospasm was tested in 76 postoperative children randomized to receive either acupuncture with bloodletting at the Shao Shang acupoint on both thumbs just prior to extubation, or to a control group (Lee, Chien, Hsu, et al., 1998). Patients undergoing oropharyngeal surgery were not enrolled. Laryngospasm was defined as occuring within 2 minutes of extubation, characterized by stridor, silence resulting from total closure of the vocal cords, and cyanosis. In patients in the acupuncture group, 2/38 (5.3 percent) developed laryngospasm, whereas 9/38 (23.7 percent) did in the control group. No patients required reintubation.

(7) This study (Jiang, Kao, and Wang, 1999) tested the use of NIPPV postextubation. Enrolled patients were 93 extubated individuals, 56 of whom were electively extubated and 37 of whom had unplanned extubations. Patients were randomized to either BiPAP delivering IPAP 12 cm H_2_O and EPAP 4 cm H_2_O, by face mask for up to 72 hours, temporarily removed for suctioning and eating, or to oxygen therapy. Patients in both arms had arterial blood gases measured 1 to 3 hours postextubation. BiPAP was terminated and patients were intubated if arterial blood gases deteriorated, or if labored breathing or hemodynamic stability developed. Extubation failure was defined as the need for reintubation as judged by the attending physician. Patients had similar preextubation blood gases. The oxygen group had 7/46 reintubations, whereas the BiPAP group had 13/47 reintubations (not significantly different). The postextubation management with or without NIPPV therefore did not influence outcome, however, compared with the elective extubation patients (6/56), the unplanned extubation patients were more likely to be reintubated (14/37).

## Observational Studies Addressing Prediction of Successful Weaning and Duration of Ventilation

### Clinical and Methodologic Details of Observational Studies (Evidence Tables 11, 12, and 13)

We identified 68 observational studies described in 72 articles. Most were published in English; in addition, two were in Spanish, one was in Italian, one was in Russian, and one was in Japanese. As indicated in Evidence Table 11, approximately one-half of the studies were done in heterogeneous general ICU patients, whereas a substantial minority were in more homogeneous populations such as cardiac surgery patients. Most of the studies were unblinded; that is, individuals making decisions about weaning and/or extubation readiness were aware of the results of the variables being analyzed as potential predictors by the investigators. Most studies did not mention whether patients had a tracheostomy, how decisions to perform tracheostomy were handled in the study protocol, or whether this procedure was taken into account during analysis. Evidence Table 11 also lists the main outcomes used by these observational studies. The majority of studies evaluated predictors of one the following outcomes: (1) successful stepwise decrease in mechanical support; (2) successful discontinuation assessment; (3) successful extubation; (4) successful discontinuation assessment and extubation; (5) combinations of 1, 2, and 3; (6) successful weaning and extubation at any time; (7) the duration of ventilation in COPD patients; and (8) the duration of ventilation in cardiac surgery patients.

The clinical and methodologic details of observational studies of weaning predictors are provided in Evidence Table 12. Studies are grouped according to the outcomes they endeavored to predict. These outcomes are either binary (outcomes 1-6) or continuous, representing duration of ventilation (outcomes 7 and 8). Evidence Table 13 presents the results of each study of weaning predictors, listing all of the predictors examined and the outcomes evaluated. Therefore, Evidence Tables 12 and 13 provide the most comprehensive picture of the observational studies of weaning predictors, and their findings. The total number of predictors tested in these studies is 462. The most important of these predictors will be discussed in more detail in later sections of this report.

We found only one study showing that a nursing intensity index was associated with duration of ventilation in COPD patients (Thorens, Kaelin, Jolliet, et al., 1995). Ten studies examined myriad predictors associated with duration of ventilation in cardiac surgery patients, most of which relate to preoperative, operative and postoperative cardiovascular and cardiorespiratory physiology.

### Weaning Variables with Predictive Power (Evidence Table 14)

Evidence Table 14 describes the most important predictors of weaning or extubation success in this review, grouped according to predictor variables. We describe the methods by which we arrived at this list of predictors in an earlier section of this report. In Table 14 described below, we did not consider the results of either outcome (5) or (6) because of the difficulty interpreting the predictive power of complex, multidimensional outcomes that were sometimes nontransparently reported.

Evidence Table 14 shows the most accurate and powerful predictors of weaning or extubation success based on our review. To aid in the interpretation of Evidence Table 14, the following summarizes the outcomes associated with the first predictor listed. Prior duration of mechanical ventilation was an accurate predictor of a variety of weaning outcomes in 17 studies. Five studies reported duration of ventilation measured in hours, 11 measured it in days, and one study used a threshold for duration of ventilation of 10 hours. Duration of ventilation was associated with two outcomes as listed in the second column of Evidence Table 14. Considering the predictive power of duration of mechanical ventilation measured in days, there were two studies in which duration of ventilation predicted successful discontinuation assessment, four studies in which duration of ventilation predicted successful discontinuation assessment and extubation, and five studies in which it predicted successful extubation.

For the predictors listed in Evidence Table 14, accuracy is reported in one or both of two ways as determined by the data reported in the original articles: comparing means and variances in groups of patients who were successful or not successful in their wean, or as the sensitivity and specificity of defined thresholds (e.g., respiratory rate <35) for a given predictor. For example, the accuracy of respiratory rate as a weaning predictor is reported both with specified thresholds (6 studies), with a threshold that is not reported (1 study) and without specified thresholds (13 studies). Among the 13 studies in which the predictive value of respiratory rate was measured without a threshold, we found that it was predictive of successful discontinuation assessment in two studies, predictive of successful discontinuation assessment and extubation in seven studies, predictive of successful extubation in three studies, and predictive of a successful decrease in mechanical support in one study. Among the 6 studies in which respiratory rate was analyzed using a threshold, we found that a respiratory rate of <38 breaths/minute was predictive of successful discontinuation assessment and extubation (combined) in two studies, that a respiratory rate of <35 breaths/minute was predictive of successful discontinuation assessment and extubation in one study, that a respiratory rate of <30 breaths/minute was predictive of successful discontinuation assessment and extubation (one study) and successful extubation (one study), and that a respiratory rate of <22 was predictive of a successful decrease in mechanical support in one study. Several studies analyzed the predictive power of respiratory rate using more than one metric so the number of studies cited above bearing on the predictive power is greater than the total number of unique studies evaluating this predictor.

Two weaning predictors listed in Evidence Table 14 were indexed to body weight: tidal volume and rapid shallow breathing index. Considering tidal volume, this was reported in 21 studies using 4 metrics: tidal volume with no specified threshold, tidal volume expressed in milliliters per kilogram, tidal volume with a specified threshold, and tidal volume expressed in milliliters per kilogram using a specified threshold. As with respiratory rate and other predictors in this review, some studies evaluated the predictive power of tidal volume using several metrics. Among 13 studies reporting tidal volume with no specified threshold, we found that tidal volume was predictive of successful discontinuation assessment (one study), predictive of successful discontinuation assessment and extubation (six studies), and predictive of successful extubation (six studies). In the three studies in which tidal volume was expressed in milliliters per kilogram, it was found to predict successful discontinuation assessment (one study) and extubation success (two studies). Among six studies reporting tidal volume with a specified threshold, tidal volume >325 ml was predictive of successful discontinuation assessment and extubation (two studies), tidal volume >325 ml was predictive of successful extubation (one study), tidal volume >325 ml was predictive of successful discontinuation assessment (two studies), and finally, tidal volume >360 ml was predictive of successful discontinuation assessment and extubation (one study). Among three studies reporting tidal volume in milliliters per kilogram and using a threshold, tidal volume expressed as milliliters per kilogram >4 was predictive of successful discontinuation assessment and extubation (two studies); in another study, two thresholds were examined and found to be predictive of successful extubation: tidal volume expressed as milliliters per kilogram >4 and >6 (one study).

A total of 24 studies evaluated the predictive power of the rapid shallow breathing index, with various thresholds (18 studies) or without thresholds (9 studies) or standardized to body weight (1 study). Rapid shallow breathing index will be discussed in more detail when we present the results of the Evidence Table 15.

Occlusion pressure was tested in eight studies. Whether evaluated with or without a threshold, it appears to be a fairly weak predictor of weaning success, whether defined according to successful discontinuation assessment, extubation, or a combination thereof.

One section of Evidence Table 14 lists five important predictors of duration of ventilation in cardiac surgery patients identified in four studies. These include coronary artery bypass grafting (CABG) as compared with other surgical approaches, total operating room time, fentanyl dose, midazolam dose, mean arterial blood pressure, and patient age.

Evidence Table 14 presents the results of studies in which the magnitude of the predictive power is not reported; rather, predictive power is expressed as a beta coefficient p value from regression analysis. Most of the predictor variables listed have been tested for their association with the duration of ventilation in cardiac surgery patients. These predictors include those related to preoperative morbidity (e.g., prior myocardial infarction), pre-ICU respiratory mechanics (e.g., percent predicted forced expiratory volume at 1 second [FeV_1_]), surgical issues (e.g., second cardiac surgery procedures), postoperative events (e.g., new Q-waves on electrocardiogram). One study fulfilling criteria for data presentation in Evidence Table 14 identified three predictors of successful extubation: tidal volume, oxygen requirement, and oxygenation index.

Evidence Table 14 also presents the predictive value of variables that were found to be accurate predictors in just one observational study, with a sample size of fewer than 50 patients.

### Pooled Analyses of Predictor Studies (Evidence Table 15)

Evidence Table 15 presents the pooled results of the observational studies of weaning predictors for each outcome evaluated in more than three studies. Each row describes the predictive power of one predictor. Studies using binary data are presented first, then studies using continuous data. All studies contributing to the pooled likelihood ratios are included, along with the threshold used to generate each likelihood ratio when provided by the investigators.

In the first section of Evidence Table 15, we describe the only variable found to predict a successful stepwise decrease in mechanical support: respiratory rate. Respiratory rate <38 was predictive of a successful outcome in two studies, both of which reported respiratory rate using continuous data. The study-specific likelihood ratio associated with a value of <38 (LR +, < 38 being a "positive" result) and the likelihood ratio associated with a value of >38 (LR, >38 being a "negative" result) is reported here. Note that in this, and all other circumstances, we considered a positive results as increasing the probability of successful weaning and a negative result as reducing the probability of successful weaning. The pooled likelihood ratios are 1.1 (0.95, 1.28) and 0.32 (0.06, 1.71). This indicates that a respiratory rate of <38 leaves the probability of successful weaning virtually unchanged, but a value of >38 leads to a moderate reduction in the probability of successful weaning (although the CI around the LR is very wide). The corresponding summary odds ratio is 3.57 (0.57-22.47), and sensitivity and specificity are also provided.

In the second section of Evidence Table 15, we describe the six relevant variables tested for their ability to predict successful discontinuation assessment: minute ventilation, respiratory rate, tidal volume, rapid shallow breathing index, negative inspiratory force, and PI_max_. Each of these variables were contributed to by binary data and continuous data. The individual study LRs are close to 1. The study by del Rosario, Sassoon, Chetty, et al. (1970) showed that respiratory rate of <38 was a significant predictor of a successful trial of unassisted breathing (LR 1.63 (1.10, 2.62). However, the power of this predictor is modest. The pooled LR associated with a respiratory rate of <38 is 1.25 (0.85, 1.84). PI_max_ was examined in the same three studies. The individual study LRs are reported, and the pooled LR is 1.15 (0.98, 1.35).

In the third section of Evidence Table 15 presents the studies examining relevant predictors of successful extubation (minute ventilation, respiratory rate, rapid shallow breathing index, rapid shallow breathing index standardized to body weight, tidal volume, PI_max_, and P_0.1_/MIP). Of greatest interest is the rapid shallow breathing index, reported in 10 studies, 9 of which used similar thresholds of 100 to 105 breaths/L/min. Individual study LRs range from 0.84 (0.61, 1.16) to 4.67 (2.42-8.99). The pooled likelihood ratio from 10 studies was 1.49 (1.11-1.99), suggesting that the rapid shallow breathing index may be a reasonably strong a predictor of extubation success. When the rapid shallow breathing index is standardized to body weight, its power marginally increased (LR 1.79, 0.98-1.40). The only predictor in which a positive test led to appreciable increases in likelihood of successful extubation was P_0.1_/MIP, which is associated with 2 individual study LRs of 2.7 (0.57, 12.83) and 2.14 (1.03, 4.46), respectively. The pooled LR of 2.23 (1.15, 4.34) represents a statistically significant and marginally clinically useful predictor of successful extubation.

In the fourth section of Evidence Table 15, we present the studies examining relevant predictors of successful spontaneous breathing assessment and extubation, combined (minute ventilation, respiratory rate, tidal volume, rapid shallow breathing index, NIF, PI_max_ and P_0.1_/MIP). For this outcome, the rapid shallow breathing index appears to be a good predictor, as shown in the eight studies listed. In four studies, the LR was significantly greater than one. Pooling data from the four studies in which information was presented in binary form yielded a statistically significant LR of 1.50 (1.23, 1.38). The predictor of P_0.1_/MIP also yielded a useful pooled likelihood ratio of 16.25 (2.35, 112.5); however, the data contributing to this variable are sparse and this value may be spuriously high.

In the fifth section of Evidence Table 15, we present the studies examining relevant predictors of the outcome of a successful stepwise decrease in mechanical support (minute ventilation, rapid shallow breathing index, and NIF). Although minute ventilation is an unhelpful predictor, the rapid shallow breathing index was marginally helpful in both septic and nonseptic patients, generating a likelihood ratio of 1.53 (1.13, 2.08).

In the final section of Evidence Table 15, we present the study evaluating the only variable relevant predictor of duration of ventilation in cardiac patients: having had a coronary artery bypass graft. This was not a statistically significant predictor of duration of mechanical ventilation.

### Summary ROC Curves (Figures 1-8)

Summary ROC curves deal with the problem of different thresholds among studies. We show the summary ROC curves for several predictors of two main outcomes: successful extubation (Figures 1-3) and successful discontinuation assessment and extubation (Figures 4-8).

Figure 1. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: minute ventilation; outcome: successful extubation

Figure 3. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: rapid shallow breathing index (RSBI); outcome: successful extubation

Figure 4. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: minute ventilation; outcome: successful discontinuation assessment and extubation

Figure 8. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: maximal inspiratory pressure; outcome: successful discontinuation assessment and extubation

Figure 1 displays the summary ROC curve for minute ventilation as a predictor of successful extubation. Figure 2 displays the ROC curve for respiratory rate as a predictor of successful extubation. Figure 3 displays the summary ROC curve for the rapid shallow breathing index as a predictor of successful extubation.

Figure 2. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: respiratory rate; outcome: successful extubation

Figures 4-8 show the strength of several variables predicting successful discontinuation assessment: minute ventilation (Figure 4), respiratory rate (Figure 5), tidal volume (Figure 6), rapid shallow breathing index (Figure 7), and PI_max_ (Figure 8).

Figure 5. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: respiratory rate; outcome: successful discontinuation assessment and extubation

Figure 6. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: tidal volume; outcome: successful discontinuation assessment and extubation

Figure 7. Weaning predictor analysis: summary receiver operating characteristics curve Predictor: rapid shallow breathing index (RSBI); outcome: successful discontinuation assessment and extubation

Testing for the presence of a threshold for Figure 1, the regression coefficient is 0.23 (p value 0.38), indicateing that there is no evidence of a threshold effect for minute ventilation as a predictor of successful extubation. Similarly, testing for a threshold effect for Figure 2, the regression coefficient is 0.45 (p value 0.19), indicating that there is no evidence of a threshold effect for respiratory rate. The same holds for rapid shallow breathing index, for which the coefficient is -0.30 (p value 0.29).

There is no evidence of a threshold effect for any of the predictors of successful discontinuation assessment and extubation: minute ventilation (coefficient 0.09, p value 0.89), respiratory rate (coefficient 0.11, p value 0.66), tidal volume (coefficient 0.30, p value 0.38), rapid shallow breathing index (coefficient 0.18, p value 0.48), and PI_max_ (coefficient 0.02, p value 0.93).

ROC curves can be used to compare two or more different signs or tests. The one lying furthest to the top left corner is the most accurate; this value is where sensitivity and specificity are highest. Of these eight summary ROC curves, none appears to be much more powerful than the others. For the three predictors that are graphed twice (minute ventilation, respiratory rate, and rapid shallow breathing index, which predict both successful extubation and predict successful spontaneous breathing discontinuation and extubation), we did not test for significant differences between the summary ROC curves, since we did not have the recommended 10 studies represented in each ROC curve (Moses, Shapiro, and Littenberg, 1993). This rationale precluded our testing for significant differences across all summary ROC curves.

## Qualitative Studies of Weaning From Mechanical Ventilation

In this section, we describe the results of the qualitative studies in this field, which offer insight into social, emotional, and experiential phenomena. In contrast, quantitative studies (such as epidemiologic investigations and clinical trials) aim to test well-specified hypotheses concerning a few predetermined variables. The first study in this section on qualitative research will be described in detail to explain how specific critical appraisal criteria can be used to interpret and understand qualitative research reports.

### Qualitative Research of Nursing Experience

(1) The goal of the Jenny and Logan, 1994 study was to develop a theory to describe the nursing process in weaning. The specific objectives were to identify nurses' knowledge, judgments, and actions during ventilator weaning.

#### A. Is This Study Valid?

· Were participants relevant to the research question and was their selection well reasoned?

This critical appraisal criterion should examine whether the study was designed to address its research question and whether it was conducted rigorously to achieve its objectives. Participants were 16 nurses in a large teaching hospital in Ottawa, Canada, identified by their supervisor as being experts in weaning. They had a range of 5 to 25 years of ICU experience. Since the goal was to describe "the nursing process" in weaning, it is appropriate to ask nurses about their views.

· Were the data collection methods appropriate for the research objectives?

The most common approaches to collecting qualitative data involve one or more of field observations, interviews, and document analysis. The data collection methods should put the researchers in a position to observe the social behavior and communications that they seek to describe. Nurses were asked to provide a written account of an incident in which they believed they made a difference to patient outcome in ventilator weaning situations. A document analysis was not conducted, but the incident was used to focus the interview discussion. Individual interviews such as these tend to be useful for evoking personal experiences and perspectives. However, the domains of exploration, questions, probes, and prompts for the interview were not reported. Thus, the data collection process could have been more transparent.

· Was the data collection comprehensive enough to support rich and robust descriptions of the observed events?

Data collection needs to be comprehensive enough in both breadth (types of observations) and depth (extent of observation of each type) to generate and support the interpretations. In this study, the audiotapes of all interviews were transcribed and examined line by line for coding with key phrases. Data collection and analysis proceeded concurrently from the first interview and are described in the next section.

· Were the data appropriately analyzed and the findings adequately corroborated?

Qualitative researchers begin with a general exploratory question and preliminary concepts; then collect relevant data, observe patterns in the data, and organize these into a conceptual framework; and then resume data collection to both explore and challenge this conceptual framework. Investigator triangulation was conducted through consensual coding by two investigators, both of whom were nurses. It would have been interesting to obtain additional insights from investigators from a different discipline. Member checking was done by sharing the findings with study participants as well as other nursing groups. Throughout the course of the study, published literature was examined to validate concepts that emerged from the literature and clarify theoretical meanings. This suggests that through this grounded theory approach, the conceptual findings did develop as a result of the empirical observations.

#### B. What are the results?

· How evocative and thorough is the description?

The product of a qualitative study is a narrative. The use of examples and reference to sources gives the reader insight into the nature of the social phenomenon as well as the sensibility of how investigators interpreted it. The results of this study are clearly written. The narratives are liberally illustrated with excerpts from interviews, which give readers more intimate insight into the nurses' perspectives. The excerpts also support the authors' interpretations of the structure of these discussions (i.e., as dyadic and goal-oriented). The information is rich and coherently organized.

· How comprehensive and relevant are the theoretical conclusions?

-What major and minor concepts does the theory entail, and how well-defined are they?

The core category of this grounded theory approach was Promoting Patients' Ventilator Independence. Three themes emerged: knowing the patient, work of weaning, and managing patient energy. Knowing the patient reflected the nurses' self-directed interventions and advocacy activities during weaning; in development of this theme, nurses identified specific situations that demonstrated how they established trust and credibility with the patient. The working of weaning theme was about how nurses prepare patients physically and psychologically to do the work of weaning, and how they enhance focus and try to relieve stress. The theme of managing energy was about how nurses help to ensure optimum energy resources for weaning, how nurses play a key role in conserving patient energy, and how they help to focus energy on the process of weaning.

-Are the concepts adequately developed and illustrated?

The conceptual categories make sense and are well described. The liberal use of illustrative excerpts and interpretive description offer the clinical reader vicarious experience and a unique vantage on nursing perspectives on their role in helping patients wean from mechanical ventilation.

-Where does the empirically generated theory fit in relation to established theory and beliefs in the field?.

This study did develop a clear, overarching conceptual framework to describe nurses' knowledge, judgments, and actions during ventilator weaning. These results are organized in tables and text illustrating key concepts and their relationships. There is little mention of existing theory in other literature.

#### C. How can I use the results?

· Does this study help me to understand the context of my practice?

· Does this study help me to understand my patients and their families?

This study provides a distinct nursing perspective on the process of promoting ventilator independence. The study goes beyond many qualitative reports by including a section on nursing implications, thereby actualizing the study results. Many implications relate to patient empowerment (a popular topic in the nursing literature, but uncommon in the weaning literature). A discussion of how to interpret and apply the framework ensues. A table to aid in identifying a dysfunctional ventilator weaning response is included.

(2) A second article by Logan and Jenny from 1990 (Logan and Jenny, 1990) was published before the one published in 1994 (Jenny and Logan, 1994, summarized above). The 1990 publication contains the same methodology but less richly interpreted results. Therefore, we have only summarized and critiqued the 1994 publication in detail.

(3) A third report by Jenny & Logan (Jenny and Logan, 1991) based on the same data was a more detailed interpretive analysis to develop a new nursing diagnosis of the dysfunctional ventilatory response. In this report, the conceptual underpinnings of this diagnosis were more developed, and five themes emerged. These themes included knowing the patient (which was the basis for expert nursing judgment), acknowledging the work of weaning, developing a trusting relationship, the patient power base (constituting two dimensions-physical energy and perceived self control) and situational factors (nurses' perceptions of elements necessary for a controlled predictable environment). Through this qualitative research we learn how expert nurses conceptualize the facilitation of a new nursing diagnosis of the dysfunctional ventilatory weaning response.

(4) A fourth article by Logan and Jenny (Logan and Jenny, 1991) presents ideas focused on three main interventions that nurses could engage in to optimize the weaning experience. The first category of interventions were considered situational-related factors. Participants raised the following interventions: establishing patient trust, controlling and enhancing social support, modifying the environment, and advocacy. The second category was physiologic factors; the associated interventions were ensuring nutrition, resting the patient, and training techniques to pace the tempo of the wean. The third category was psychological factors; the associated interventions were teaching patients, addressing impaired self-esteem and hopelessness, improving self-efficacy, coaching, and providing support. This study provides a framework for how nurses can best help patients who are weaning from mechanical ventilation by addressing their interventions to target the three categories of patient need.

### Qualitative Studies of Patients' Experience

(1) In an early qualitative study using participant observation (Mendal and Khan, 1980), these investigators explored to what extent psychosocial factors might contribute to difficulty weaning patients with COPD from mechanical ventilation. Over 1 year in a respiratory ICU, the psychiatry service was consulted for 10 patients. Of these, four patients representing 2.2 percent of all ICU admissions met physiologic criteria for weaning; however, they were considered to have a major impediment to the weaning process on the basis of "emotional factors." Using a case study approach, these investigators describe the history of two of these four patients. Family members were interviewed for pertinent history and nurses were interviewed to elicit their assessment of patient anxiety. Patients were asked to self-report on the Zung Depression Scale, but their competence and ability to engage was not described. In terms of the validity of this qualitative report, the type of participant was appropriate to the objective of the study, but the rationale for describing these two cases was not provided. Interview guides, transcribed tapes, and analysis of information are not reported; therefore, we cannot judge whether data collection methods are comprehensive and appropriate to the study objectives. Descriptions of the observed events are minimal, and they are poorly corroborated.

Through undisclosed methods, a retrospective attempt was made to develop criteria for the early identification of failure to wean being a result of psychosocial or emotional factors. In the results section, new methods are introduced whereby patients who have difficulty weaning are compared with those who do not. Patient self-reports of depression were considered unreliable. Investigators could not identify predictors of emotional impediments contributing to weaning failure but suggested that recent object loss (the first patient had this) or psychiatric treatment (the second patient had this) might be important. The results of this study are described in a cursory manner, made more difficult to understand in light of the vague methodology. The description is not evocative, the analysis is not faithful to the data, and no theory is provided. However, some recommendations are made, albeit not based on evidence from this study. This may have been one of the early studies making the reasonable suggestion that sometimes weaning difficulty is associated with emotional factors and that patients who meet physiologic criteria for weaning but who are not progressing should be evaluated by a multidisciplinary health care team. Suggestions are made about judicious use of antidepressant or psychotropic medication if appropriate.

(2) An objective of another study (Jablonski, 1994) ) was to understand the experience of patients who required mechanical ventilation. Twelve patients who had been ventilated for at least 18 hours were recruited through the use of classified advertisements. A rationale for how these individuals were selected is not provided. Interviews were conducted in the participants' homes for 9/12 individuals and 3/12 were conducted through telephone interview. Usually telephone interviews are suited to structured, directed questioning compatible with quantitative methods of eliciting either subjective or objective data; such an approach also changes the interaction between interviewer and participants and precludes interpretation of body language that might be recorded in field notes. Each lasted 20 to 90 minutes and involved general questions and compare/contrast questions. Participants were asked to describe their thoughts, feelings, and actions at the time they initially realized they being ventilated, during the time they were ventilated, and at the time they were removed from the ventilator. The interactions and communication between participants and hospital personnel were probed. The interviews took place 2 to 108 months (mean of 31 months) after mechanical ventilation. Audiotapes were transcribed verbatim. Field notes were used (it is not reported for whom or on what basis these were taken). Coding was done using indicators which were transformed into themes, which were then clustered into similar themes. Though the data collection methods were reasonably well described, their comprehensiveness for the study objectives is less clear. The analysis was done by one person, and no triangulation methods are described.

Participants generated 15 thematic clusters: preventilation event; realization of the respirator; proximity of death; patients' responses to the ventilator; responses to the endotracheal tube or tracheostomy; physical care and therapies experienced by mechanically ventilated patients; effect of mechanical ventilation on senses; communication; role of significant others; mechanical ventilator mishaps; interactions between patients and health care providers; the process of weaning; extubation and ventilator removal; aftereffects of mechanical ventilation; and recommendations from patients.

The cluster relating to the process of weaning was brief but described the difficulty and frustration associated with the process. Patients complained of the readjustment in breathing pattern after being put back on the ventilator and clearly distinguished the sensation of unassisted from assisted. They linked being off the ventilator with improvement, and one realized that the longer the time off the ventilator, the greater the improvement in health. Recommendations for the ICU team generated by these participants included more explanations about the ventilator, including what to expect and the fact that sometimes the patients' breathing is not going to match the pattern of the ventilator. One quotation is provided from a participant who would have preferred knowing, "you can relax and try to get back in synch with it, or let the nurses know you are waking up." Participants also requested receipt of concrete coping strategies while on the ventilator.

Theory is not developed in this report, and the results are not generalized to theory. Nevertheless, many of the excerpts in this report and their interpretation are compelling. In summary, the dominant communication pattern between nurse and patient was described as exchange of factual information by the nurse. This investigator found that some participants emerged from their experience of mechanical ventilation with some memories that scarred them. They described some unhelpful interventions such as being told to "calm down and relax" in the face of patient-ventilator dysynchrony. The dominant feelings were frustration and helplessness.

(3) The objective of the next study (Jenny and Logan, 1996) was to examine the meaning of metaphors used by critical care patients about their ventilator weaning experience. Twenty patients from a teaching hospital in Ottawa, Canada, were invited to participate in a study in which they were interviewed within 5 days of transfer out of ICU. An open-ended interview guide and an interactive approach were used for each 20- to 45-minute interview. Patients had been ventilated 32 days (range 5 to 214 days), and weaning had lasted a mean of 15 days (range 1 to 45 days) in this convenience sample of patients who survived ICU and successfully weaned. Data collection methods are briefly described, but the method of analysis is not. Triangulation by another investigator, discipline or data collection method is not mentioned.

In this report, four categories of metaphors resulting from the analysis are discussed in ascending order of frequency: physical discomfort, nurse caring, altered self, and patient work. Excerpts such as "breathing for my life," "couldn't tell my brain to breath" were illustrative. Although many phrases were presented, only some were metaphors. The authors did not make distinctions among semiotic elements (e.g., metaphors, signs, symbols, and narrative fragments). Although metaphors can be used to organize narratives and create imagery for constructing narratives that others find compelling, in this study the metaphors were the ends themselves rather than the building blocks for narratives. No theoretical conclusions were provided in this report. Nevertheless, some interesting metaphors and related ideas are expressed in this paper regarding the foundation of the care and comfort attributed to nurses during weaning.

(4) This report by Logan and Jenny in 1997 (Logan and Jenny, 1997) is from the same database as that described in the paper by Jenny and Logan published in 1996. The objective is to examine patients' subjective experiences of mechanical ventilation and weaning. Additional methodologic detail is provided, including the 10 interview questions that were conceived based on prior qualitative research providing insights about nurses' perceptions of the weaning process. Data collection stopped at the point of informational redundancy. Coding was done in duplicate, interpretation iterated with data collection, and triangulation was conducted with the research associate, peer debriefing, and an external qualitative research and critical care expert.

There were four themes arising from patients about ventilation and weaning: sense making, enduring, preserving self, and controlling responses. The study revealed that patients experienced physical, cognitive, and emotional work. A table was provided which links each of these four themes to the underlying patient concern, the patient strategy, and the nurse strategy that can be used to help with the domain of work experienced by the patient. This qualitative report contains useful practical implications for nurses.

(5) Another qualitative study of patients' perceptions of uncertainty and stress during weaning (Wunderlich, Perry, Lavin, et al., 1999) had several objectives: to determine levels of stress, determine the helpfulness of information from nurses and the influence of other variables, and explore patients' perceptions. After extensive pretesting by an expert panel and pilot interviewing, eight open-ended questions were asked of 19 extubated patients, and qualitative data were content analyzed and coded into themes.

Most patients experienced extreme uncertainty and stress during weaning; patients with underlying pulmonary disease compared with those without underlying disease and women compared with men had worse experiences. The dominant feeling patients described was discomfort while weaning, and the second prominent theme was frustration at the inability to communicate; in particular, patients were afraid because they did not know what to expect or what was going on or whether they would be on the ventilator for the rest of their lives. Patients were very appreciative of information provided by ICU nurses during weaning. This study clearly shows the stress and uncertainty of patients undergoing weaning and the valuable role that ICU nurses play in providing information that can reduce these adverse experiences.

In summary, these five qualitative studies provide insights about the experience of patients and nurses about the weaning process. Most studies used in-depth personal interviews as a data collection method and a grounded theory analytic approach. Although clinical directives are not typically generated from studies using interpretive methodology, several reports described above give us insight about patients' experiences and provide action-oriented recommendations to consider in practice.

## Observational Studies Describing Patient Experience During Weaning

We identified four observational studies of patient experience during weaning that did not directly address our research questions and did not allow data extraction in tables. However, given the importance of understanding patient experience during weaning, we summarize them in narrative form here. These studies provide quantitative information; in the prior section on qualitative studies, we have described complementary results from studies of patient experience conducted using qualitative methodology.

(1) The objective of the first study (Bouley, Froman, and Shah, 1992) was to compare patient experience during SIMV, T-piece, and pressure support weaning and relate these to physiologic variables. Nine COPD patients ventilated for 4 to 18 days were included in a nonrandomized crossover study; all patients were observed for four weaning trials using two weaning modes. Dyspnea was measured on a visual analog scale; and its properties of sensitivity, validity, and reliability in ventilated patients were reported. In addition, 20 observations each of heart rate, respiratory rate, minute ventilation, and oxygen saturation were made. Patients had both SIMV 4 and T-piece (N=6) or SIMV 8 and pressure support (N=3) periods.

Dyspnea was no different between modes. Physiologic measures and type of weaning did not predict dyspnea ratings using regression analysis. Individual patient regression analyses differed, however, such that different variables predicted the dyspnea ratings in different patients. Physiologic responses and subjective experience of dyspnea therefore appear to have distinct patterns across patients in this small study.

(2) The objective of the second study (Lowry and Anderson, 1993) was to learn about patients' feelings, their perceptions of hope and social support, and their notion of the locus of control during weaning, including how these change over the weaning process. Ten alert and oriented mechanically ventilated patients who were physiologically ready to wean and who had undergone two to five failed weaning attempts underwent extensive testing using several instruments. The instruments used included the Multidimensional Health Locus of Control Scales Form which uses Likert scales to measure issues of power and control, a Hope Scale measured using a visual analog scale, the Norbeck Social Support Questionnaire which contains a 9-item 5-point scale about support structures, and the Anderson-Lowry Ventilation Scale with 10 items about fear and other responses to mechanical ventilation. The validity and reliability data for each instrument were provided when possible. There were 2 interviews per patient, but only 4 of 10 patients completed both.

Mechanical ventilation was reported as a moderately fearful experience, and fear decreased over time. During ventilation, patients felt as though the locus of control was external to themselves, reflecting the intense dependence they have on the ICU team and family members. Hope increased as time passed since successful weaning, and hopelessness predominated for patients who continued to require mechanical ventilation. This study reported properties of the instruments used and captured some important experiences of patients while weaning-lack of a sense of mastery, hopelessness, and fear. As time passed and patients were weaned, the locus of control was internalized, and patients were more hopeful and less fearful.

(3) The objective of the third study (Pochard, Lanore, Bellivier, et al., 1995) was to evaluate psychological status in 43 consecutive patients who had undergone successful weaning 48 to 96 hours earlier using an interviewer-administered 32-item questionnaire with visual analog scales. Almost all patients had received opiates, benzodiazepines, or neuromuscular blockers during their ICU stay but had none for 48 hours before the interview. Of the 43 patients, 9 had suffered a cardiac arrest during their ICU stay and 9 had a prior psychiatric history. Interviewer training, validation, and technique are not reported. Results are reported in text format without means or standard deviations. Myriad difficult experiences were recorded, including an inability to communicate, sleep disorders, dreaming, diffuse anxiety, fear of abandonment by staff, and depression. Patients could not recall distinguishing between night and day (N=23), reported being confused during weaning (N=15), and had hallucinations (N=9).

(4) The objective of this study (Menzel, 1997) was to examine patients' responses to communication during intubation and 7 days afterwards, following extubation, and to relate these to situational and demographic variables. Among 29 oriented patients from 4 ICUs who were intubated for at least 24 hours, questions were asked using the Emotion Scale and the Ease of Communication Scale, for a total of 23 items each using a Likert scale. Validity and reliability data are reported on these scales when possible.

There were no significant differences between the intubation and postextubation data overall, but one-third of patients reported differences of 20 percent or more between time periods. There were no correlations with situational and demographic variables. Women tended to report more fear of being unable to speak postextubation than during intubation; men reported less fear. Patients recalling less difficulty with communication had shorter periods of intubation. The emphasis on this report was on correlations and pre-post comparisons; relatively sparse data describe patients' perceptions.