# Methodology

## Eligibility Criteria

We resolved to retrieve all randomized trials that addressed the AHRQ review questions. Conceptually, we were interested in any patients receiving mechanical ventilation in an intensive care setting, any strategies designed to facilitate weaning and extubation, any predictors of weaning and extubation in all critically ill patients, and predictors of the duration of weaning in patients with chronic obstructive pulmonary disease (COPD) or patients following cardiac surgery. Appendix G shows our relevance form and Appendix H provides a list summarizing our inclusion and exclusion criteria.

### Study Designs

We included randomized trials, controlled clinical trials, observational studies, qualitative studies of patients' and nurses' experience of weaning, and quantitative studies describing patients' experience of weaning. We excluded single case reports and case series or observational studies of fewer than 20 patients because of the possibility of selection bias. We excluded unpublished PhD theses.

### Publication Types

We included relevant primary studies with designs as described above. We excluded editorials, letters to the editor, unpublished research, position papers, consensus conference reports, practice guidelines, and narrative or systematic reviews.

### Populations

We included all studies of adult and pediatric patients who were mechanically ventilated and had either an endotracheal tube or tracheostomy tube. We excluded studies of highly specific populations (e.g., obstructive sleep apnea, flail chest, and Guillain-Barré syndrome) and studies focused on ventilator associated pneumonia. We also excluded studies in neonates, since these have been summarized in recent systematic reviews of the Cochrane Collaboration.

### Settings

We included studies conducted in ICUs and intermediate care units. We excluded studies of home ventilation for children or adults and chronic ventilation settings.

### Interventions

We included any ventilation or weaning strategy (e.g., mode, method, procedure, protocol, timing, operator, computer, tracheostomy, noninvasive ventilation modes, adjunctive holistic aids, and other miscellaneous approaches) geared to facilitate weaning and/or extubation. We excluded interventions focused on mechanical ventilation methods (e.g., lung protective ventilation strategies, high-frequency oscillation, jet ventilation, nitric oxide, and extra-corporeal membrane oxygenation) that are not directly related to weaning. We omitted interventions whose influence on the duration of ventilation has already been summarized in a recent systematic review (e.g., sedation in the ICU, timing of tracheostomy). However, we included studies evaluating anesthesia and sedation management that is integral to testing the effect of early versus late extubation in cardiac surgery patients. We excluded interventions initiated in the operating theatre and finished in the postanesthesia recovery unit (e.g., neuromuscular blockade) and interventions initiated at the onset of mechanical ventilation (e.g., fluid management).

### Predictors

We included predictors of weaning and/or extubation success and predictors of duration of mechanical ventilation in cardiac surgery and COPD patients. We excluded predictors of self-extubation. Though representative of an important body of literature in this field, we excluded studies designed primarily to evaluate the reproducibility of various predictors of weaning success or duration of ventilation.

### Outcomes

We included all clinical outcomes. We excluded studies that reported exclusively physiologic outcomes. We included studies reporting the endpoint of patients' experiences and nurses' assessments of patients' experiences to address AHRQ question 4 regarding the important role of nurses in optimizing the weaning process. We excluded outcomes from randomized trials when at least 20 percent patients were eliminated from the analysis. We excluded costs due to insufficient reporting of economic outcomes and their poor generalizability. We also excluded studies predicting terminal weaning for purposes of life support withdrawal.

## Search for Relevant Studies

To identify relevant studies, we searched MEDLINE, EMBASE, HealthSTAR, CINAHL, the Cochrane Controlled Trials Registry, the Cochrane Data Base of Systematic Reviews from 1971 to 1998, and personal files. We examined the reference lists of all included articles for other potentially relevant citations. In addition, we hand searched the respiratory therapy journal Respiratory Care from 1997 to 1999. We did not explicitly search for unpublished literature. Appendixes A to F summarize our search strategies.

Two reviewers examined each title and abstract. Reviewers included either two of the investigators or one investigator and one senior respiratory therapist. We took a comprehensive approach and retrieved all articles that either reviewer considered possibly eligible. The same two reviewers examined the full text and made final decisions regarding eligibility based on the inclusion and exclusion criteria described above. These decisions were made unblinded to the source, authors, and conclusions of each study. Disagreements were resolved by consensus.

## Data Abstraction and Assessment of Methodologic Quality

Five respiratory therapists and five intensivists participated in data abstraction and in rating the methodologic quality of all eligible randomized trials or nonrandomized controlled cohort studies addressing treatment issues and all studies providing quantitative data concerning predictors of weaning and extubation. We trained each of the abstractors and constructed manuals to help them with their task. Two reviewers abstracted the data and assessed the methodologic quality of each study. Reviewers resolved disagreement through discussion or consultation with one of the investigators. Final data abstraction was rechecked by one of the investigators.

We developed a generic data collection form applicable to both randomized trials and observational studies (Appendix I), a form particular to the randomized trials (Appendix J), a form particular to nonrandomized controlled studies of weaning interventions (Appendix K), and a form particular to observational articles providing quantitative information about weaning predictors (Appendix L).

Methodologic features of randomized trials that we abstracted included the method of randomization and whether randomization was concealed; the extent to which groups were similar with respect to important prognostic factors; whether investigators conducted an intention to treat analysis; whether patients, clinicians, and those assessing outcome were blind to allocation; the extent to which the groups received similar cointerventions; and reporting of the reasons for study withdrawal.

Because it is a relatively new methodologic term, the issue of concealment deserves further comment. A study is concealed if those making the judgment about whether a patient is eligible to be enrolled is unaware, at the time they are making this decision, whether a patient will be allocated to the experimental or control group. Lack of concealment may theoretically destroy the balance in prognostic factors that investigators strive to achieve through randomization. For instance, those making decisions about eligibility and enrollment may systematically exclude sicker patients if they know these patients are going to be allocated to the treatment group. Some empirical data suggest that unconcealed studies yield systematically larger treatment effects than do concealed studies (Moher, Pham, Jones, et al., 1998; Schulz, Chalmers, Hayes, et al., 1995).

For nonrandomized controlled clinical trials, we considered the extent to which groups were similar with respect to important prognostic factors, whether the investigators adjusted for differences in prognostic factors, and the extent to which the groups received similar cointerventions.

For studies addressing predictors of weaning success, we considered whether investigators enrolled a representative sample of patients and whether those making weaning decisions or assessing outcomes were blind to predictor variables (Jaeschke, 1994a).

For qualitative studies, we considered whether the choice of participants was relevant to the research question and if their selection well reasoned, whether the data collection methods were appropriate for the research objectives, whether the data collection was comprehensive enough to support rich and robust descriptions of the observed events, and whether the data were appropriately analyzed and the findings adequately corroborated (Giacomini, work in progress).

## Statistical Synthesis

When we found duplicate reports of the same study in preliminary abstracts and articles (Chaney, Nikolov, Blakeman, et al., 1999; Chatila, Ani, Guaglianone, et al. 1996a; Cheng, 1996b; Goodnough-Hanneman, 1992; Nava, Zanotti, Rubini, et al 1994a; Zanotti, Rubini, Iotti, et al., 1995), we used the most complete information (Chaney, Nikolov, Blakeman, et al., 1998; Chatila, Jacob, Guaglianone, et al.,1996b; Cheng, 1996b; Goodnough, 1994; Nava, Rubini, Zanotti, et al. 1994b). We divided our approaches to synthesis (and subsequently our results) into studies dealing with randomized and nonrandomized controlled comparisons of alternative weaning interventions and observational studies addressing the prediction of successful weaning and duration of mechanical ventilation.

## Controlled Comparisons of Alternative Treatments

We began by identifying all the interventions and outcomes addressed by randomized trials. We abstracted or, when necessary, calculated effect sizes in terms of relative risks and associated 95 percent confidence intervals (CIs) for binary outcomes and mean differences and 95 percent CIs for continuous variables. We transformed interquartile ranges into standard deviations when necessary to obtain variance estimates for testing differences between groups. Confidence intervals are not reported when variance data were either not provided by authors or were not estimable using either a precise p value or an interquartile range.

We reviewed the interventions and outcomes and decided when it was legitimate to pool across studies and when it was not. When pooling was not appropriate, we divided studies into categories according to similarity of interventions.

We pooled when, in our judgment, the underlying pathophysiology was such that across the range of populations, management strategies in treatment and control groups, and key outcomes studied, we would expect more or less the same treatment effect. In general, we did not see differences in distributions of characteristics of populations between studies as an impediment to pooling. For instance, consider two studies of the same weaning strategy. One enrolls patients 8 days after the onset of mechanical ventilation, and another, 14 days after. However, both studies enroll some patients after 3 days of ventilation, and others, after 3 months. Thus, the individual studies are themselves pooling data from patients with the full spectrum of duration. When interventions, outcomes, and trial methodology are similar, we do not see serious impediments to pooling in this sort of situation.

For instances in which we could pool data, for continuous variables we considered the mean in each group and an estimate of variability from each group that determined the weight given to the study in the pooled analysis. For pooling binary data, we calculated risk ratios using methods described by Fleiss (Fleiss, 1993). We constructed 2X2 tables in each study for which the data were available and calculated the associated risk ratios. For both continuous and binary variables, we tested for heterogeneity using a test based on the chi-squared distribution with N1 degrees of freedom where N is the number of studies. When we found clinically important heterogeneity that could not be explained by the play of chance, we reviewed the methodology of the original studies in search of explanations of the differences in outcome. All our analyses are based on a random effects model that incorporates differences between studies in the calculation of the the variance estimate for all treatment effects.

For nonrandomized studies that compared alternative weaning interventions, we used similar methodology for calculating point estimates and CIs for individual studies but made no attempt to pool data across studies.

## Observational Studies Addressing Prediction of Successful Weaning and Duration of Ventilation

We began by categorizing studies according to the outcome of interest (Evidence Table 13). For instance, we included studies of predictors of a successful trial of spontaneous ventilation; studies of predictors of successful reduction in ventilatory support, and studies of predictors of the duration of ventilation in patients after cardiac surgery. For each predictor in each study in which the data were available, we constructed a 2X2 table examining the presence or absence of the predictor in relation to the success or failure of the weaning process. This allowed calculation of the sensitivity and specificity of the tests and their associated 95 percent CIs as well as odds ratios and their 95 percent CIs (Simel, Samsa, and Matchar, 1991). If multiple regression analysis had been undertaken in a study, we noted the results, extracting the variables that were significant predictors in the final regression model, including their expression as beta coefficients, p values and/or and the adjusted odds ratios and their 95 percent CIs. All data included in Evidence Table 13 are extracted directly from the full text of the articles. Two variables were defined in several ways in these reports (maximal inspiratory pressure [PI_max_] and negative inspiratory force [NIF]). For purposes of data presentation and pooling, we labeled a variable as PI_max_ when investigators described maximal inspiratory pressure measured in an occluded airway after 20 seconds starting from residual volume; we labeled a variable as NIF when negative pressure was measured after at least 1 second of inspiratory effort against an occluded airway and the most negative value of three attempts was recorded.

We then organized the observational studies according to predictors of interest in Evidence Table 14. Any predictor of potential use in at least one study was considered. Because of the very large number of predictors, our goal was a manageable presentation of the data. All the predictors are included in Evidence Table 13 that presents results by study, whereas Evidence Table 14 includes only the most relevant predictors.

We defined predictors as relevant if they showed potential for differentiating success from failure. We retained all predictors for which results were presented in 2X2 tables if there was an associated LR of greater than 2 or less than 0.5 with two exceptions: first, if the threshold value for a given predictor was not specified, its test properties were not interpretable, and second, if a study showed a LR of >2 or <0.5 but the direction of prediction was in a direction that did not make sense biologically, we did not include the predictor in the Evidence Table 14. For instance, in one study, a significantly shorter duration of mechanical ventilation was found when neuromuscular disease was present than when neuromuscular disease was not present. This likely arose because only those patients with neuromuscular disease who were deemed ready for a trial of weaning were included in the study. Thus, the neuromuscular disease patients included in this study might actually wean more readily than other neuromuscular disease patients who would not be deemed ready for weaning, and they might also wean more readily than other patients in the study such as those who, for instance, were recovering from acute respiratory distress syndrome (ARDS).

When results were presented as means and standard deviations of the success and failure groups, we included predictors if the difference in means between the two groups was greater than one-half of the smaller of the standard deviations of the two groups. Finally, we included predictors with a statistically significant association with the outcome of interest when there was no information about the power of the predictor in terms of either LRs or differences in distributions of success and failure groups.

When the results differed across studies, we included the predictor unless it was not predictive in a substantial majority of the studies that included a substantial majority of the patients. For example if only one of many studies found a predictor to be of value, we included this study unless the sample size was less than 50 percent of the total sample size of all studies that examined that predictor.

We present important predictors for which we have information about the predictive power (either in terms of LRs or separations of the distribution) in Evidence Table 14. Evidence Table 14 includes predictors that were identified as important by a p value <0.05 in a regression analysis but for which we have no other information. Evidence Table 14 includes predictors if they were evaluated and found to be predictive in only one study with a sample size of not greater than 50 patients.

## Methodology For Pooling Study Results

Where appropriate, we pooled the observational data to narrow the 95 percent CIs. We did not pool results unless it was clinically sensible.

The results of the predictor studies were reported in various ways (e.g., means and proportions in patients who were successfully and unsuccessfully extubated). The investigators presented varying analyses (e.g., sensitivity and specificity, Pearson correlation coefficients, chi-square tests, student's t tests, analysis of variance, and regression). To facilitate meta-analyses, we summarized data in a common form when possible (Irwig, Tosteson, Gatsonis, et al., 1994).

Some observational studies examined predictors of successful outcome and presented these data in a manner allowing creation of a 2X2 table. Using these data, we calculated the pooled LR of a positive test result, the pooled LR of a negative test result, the pooled sensitivity and specificity of a given predictor threshold, and an associated pooled odds ratio (OR). If there were more than three studies examining a predictor with plausible and clinically important test properties, we constructed summary receiver operator characteristics (ROC) curve.

Other observational studies examined predictors of successful outcome and presented these data in using means and standard deviations in the successful and unsuccessful group. The majority of studies presented data in this manner. We tested the assumption of normality for predictors presented in this manner in several ways. First, when we had individual patient data from the original reports, we inspected this directly. Second, when we did not have individual patient data, we inspected the mean and standard deviation for skewness, noting when the value obtained by adding two standard deviations to, and subtracting two standard deviations from, the mean yielded clinically implausible values. If we could assume normality, knowing the total sample size and the number of patients in the successful and unsuccessful groups, we estimated the number of patients in each cell of a 2X2 table. Thus, we were able to compute the summary statistics as listed above for data presented in binary fashion. We used the predictor threshold most often provided by the investigators to create these LRs. We calculated CIs for all summary measures (Littenberg and Moses, 1993). We did not pool predictor data across studies in which some investigators presented their results as binary variables and others presented their results as continuous variables. Rather, we juxtapose the results, giving an indication of their consistency.

## Other Types of Studies

We classified other types of studies according to their study design and the topic areas they addressed and provide narrative descriptions of the individual study methodology and results. These include qualitative studies examining the experience of health workers involved in the care of patients being weaned from mechanical ventilation and studies using qualitative and/or quantitative methods to examine patients' experience of weaning.