# Appendix I. Extraction Form for General Characteristics fo All Studies

## General Characteristics of Studies, page 1

[image]

## General Characteristics of Studies, page 2

[image]

## General Characteristics of Studies, page 3

[image]

## General Characteristics of Studies, page 4

[image]

## General Characteristics of Studies, page 5

[image]

## General Characteristics of Studies, page 6

[image]