# Appendix H. Selection Criteria for Articles About Weaning

GENERIC INCLUSION CRITERIA

Design

i. Randomized controlled trials
ii. Observational studies
iii. Non-randomized Controlled Clinical Trials
iv. Qualitative studies

Setting

i. Intensive care units
ii. Post-anaesthetic care units

Population

i. Adults or
ii. Children with and endotracheal tube (including tracheostomy) who are mechanically ventilated

Intervention

i. Any ventilation or weaning strategy (mode, method, protocol, procedure, operator, timing, computer use, non-invasive ventilation, tracheostomy, holistic care,) that is geared to facilitate weaning and/or extubation .
ii. Measurement of predictors of weaning and extubation success.
iii. Measurement of predictors of duration of ventilation (in cardiac surgery and COPD patients).
iv. Miscellaneous interventions designed explicitly to facilitate weaning

EXCLUSION CRITERIA

Publication type

i. Editorials
ii. Letters
iii. Consensus conference reports
iv. Position papers
v. arrative or systematic reviews

Design

i. Observational studies less than 20 patients
ii. Case reports

Setting

i. Home ventilation for adults
ii. Chronic ventilation facilities

Population

i. Neonates
ii. Highly specific populations (obstructive sleep apnea, Guillain Barre Syndrome, flail chest)
iii. Specific conditions (polyneuropathy of the critically ill)
iv. Ventilator associated pneumonia (prevention, diagnosis, treatment)

Intervention

i. Studies of self-extubation
ii. Studies of sedation use, neuromuscular blockade, reversal of neuromuscular blockade.
iii. Studies about fluid administration.
iv. ECMO, NO, lung-protective ventilation strategies, HFO, HFJV, PLV.
v. Interventions initiated at the onset of mechanical ventilation except in CABG or COPD patients

Outcomes

i. Studies that examine only physiologic end points