# Appendix G. Relevance Form: Weaning from Mechanical Ventilation

We Ref ID #

Person Screening DJC MOM

Include

Exclude because:

1 Publication type
  i. Editorials
  ii. Letters
  iii. Consensus conference reports
  iv. Position papers
2 Population
  i. Neonates
  ii. Highly specific populations (obstructive sleep apnea, Guillain Barre Syndrome, flail chest)
  iii. Specific conditions (polyneuropathy of the critically ill)
  iv. Ventilator associated pneumonia (prevention, diagnosis, treatment)
3 Setting
  I. Home ventilation for adults
4 Design
  i. Observational studies less than 20 patients
  ii. Case reports
  iii. Narrative reviews
5 Outcomes
  i. Studies that examine only physiologic end points
6 Intervention
  i. Studies of self-extubation
  ii. Surgical and anaesthetic techniques
  iii. Studies of sedation use, neuromuscular blockade, reversal of neuromuscular blockade
  iv. Studies about fluid administration
  v. ECMO, NO, lung-protective ventilation strategies, HFO, HFJV, PLV
  vi. Interventions initiated at the onset of mechanical ventilation except in CABG or COPD patients

Other ____________________________________________________________________ _________________________________________________________________________