# Appendix F. Search Strategy: EMBASE for Observational Studies

- Set Search

- #1: ARTIFICIAL-VENTILATION
- #2: ARTIFICIAL-VENTILATION
- #3: explode ARTIFICIAL-VENTILATION / all subheadings
- #4: explode ASSISTED-VENTILATION / all subheadings
- #5: PATIENT
- #6: TRIGGERED
- #7: VENTILATION
- #8: PATIENT TRIGGERED VENTILATION
- #9: INTERMITTENT
- #10: MANDATORY
- #11: VENTILATION
- #12: INTERMITTENT MANDATORY VENTILATION
- #13: SIMV
- #14: IMB
- #15: IMV
- #16: POSITIVE
- #17: PRESSURE
- #18: VENTILATION
- #19: POSITIVE PRESSURE VENTILATION
- #20: PRESSURE
- #21: SUPPORT
- #22: VENTILATION
- #23: PRESSURE SUPPORT VENTILATION
- #24: NIPPV
- #25: BIPAP
- #26: MECHANICAL
- #27: VENTILATION
- #28: MECHANICAL VENTILATION
- #29: #1 or #2 or #3 or #4 or #8 or #12 or #13 or #15 or #19 or #23 or #24 or #25 or #28
- #30: WEAN:
- #31: WEAN
- #32: WEANING
- #33: WEANED
- #34: WEANS
- #35: WEAN or WEANING or WEANED or WEANS
- #36: EXTUBATE
- #37: EXTUBATED
- #38: EXTUBATION
- #39: EXTUBATES
- #40: EXTUBATE or EXTUBATED or EXTUBATION or EXTUBATES
- #41: DISCONTINUE
- #42: DISCONTINUED
- #43: DISCONTINUATION
- #44: DISCONTINUE or DISCONTINUED or DISCONTINUATION
- #45: #35 or #40 or #44
- #46: #29 and #45
- #47: DIAGNOSTIC-ACCURACY / all subheadings
- #48: DIAGNOSTIC-ERROR / all subheadings
- #49: DIAGNOSTIC-VALUE / all subheadings
- #50: DIFFERENTIAL-DIAGNOSIS / all subheadings
- #51: RECEIVER-OPERATING-CHARACTERISTIC / all subheadings
- #52: AREA-UNDER-THE-CURVE / all subheadings
- #53: SENSITIVITY
- #54: SENSITIVITIES
- #55: SENSITIVITY or SENSITIVITIES
- #56: SPECIFICITY
- #57: SPECIFICITIES
- #58: SPECIFICITY or SPECIFICITIES
- #59: PREDICTIVE
- #60: VALUE
- #61: PREDICTIVE
- #62: VALUES
- #63: PREDICTIVE VALUE OR PREDICTIVE VALUES
- #64: FALSE
- #65: POSITIVE
- #66: FALSE
- #67: NEGATIVE
- #68: FALSE POSITIVE OR FALSE NEGATIVE
- #69: LIKELIHOOD
- #70: RATIO
- #71: LIKELIHOOD RATIO
- #72: LIKELIHOOD
- #73: RATIOS
- #74: LIKELIHOOD RATIOS
- #75: PPV
- #76: NPV
- #77: ROC
- #78: PPV or NPV or ROC
- #79: PREDICT
- #80: PREDICTION
- #81:PREDICTIVE
- #82: PREDICTS
- #83: PREDICTED
- #84: PREDICT or PREDICTION or PREDICTIVE or PREDICTS or PREDICTED
- #85: INDEX
- #86: #47 or #48 or #49 or #50 or #51 or #52 or #55 or #58 or #63 or #68 or #71 or #74 or #78 or #84 or #85
- #87: #46 and #86