# Appendix E. Search Strategy: EMBASE for Intervention Studies

- Set Search

- #1: ARTIFICIAL-VENTILATION
- #2: ARTIFICIAL-VENTILATION
- #3: explode ARTIFICIAL-VENTILATION / all subheadings
- #4: explode ASSISTED-VENTILATION / all subheadings
- #5: PATIENT
- #6: TRIGGERED
- #7: VENTILATION
- #8: PATIENT TRIGGERED VENTILATION
- #9: INTERMITTENT
- #10: MANDATORY
- #11: VENTILATION
- #12: INTERMITTENT MANDATORY VENTILATION
- #13: SIMV
- #14: IMB
- #15: IMV
- #16: POSITIVE
- #17: PRESSURE
- #18: VENTILATION
- #19: POSITIVE PRESSURE VENTILATION 1873
- #20: PRESSURE
- #21: SUPPORT
- #22: VENTILATION
- #23: PRESSURE SUPPORT VENTILATION
- #24: NIPPV
- #25: BIPAP
- #26: MECHANICAL
- #27: VENTILATION
- #28: MECHANICAL VENTILATION
- #29: #1 or #2 or #3 or #4 or #8 or #12 or #13 or #15 or #19 or #23 or #24 or #25 or #28
- #30: WEAN:
- #31: WEAN
- #32: WEANING
- #33: WEANED
- #34: WEANS
- #35: WEAN or WEANING or WEANED or WEANS
- #36: EXTUBATE
- #37: EXTUBATED
- #38: EXTUBATION
- #39: EXTUBATES
- #40: EXTUBATE or EXTUBATED or EXTUBATION or EXTUBATES
- #41: DISCONTINUE
- #42: DISCONTINUED
- #43: DISCONTINUATION
- #44: DISCONTINUE or DISCONTINUED or DISCONTINUATION #45: #35 or #40 or #44
- #46: #29 and #45
- #47: RANDOM
- #48: RANDOMIZED
- #49: RANDOMISED
- #50: RANDOM or RANDOMIZED or RANDOMISED
- #51: CLINICAL
- #52: TRIAL
- #53: CLINICAL TRIAL
- #54: DOUBLE
- #55: BLIND
- #56: SINGLE
- #57: BLIND
- #58: TRIPLE
- #59: BLIND
- #60: DOUBLE BLIND OR SINGLE BLIND OR TRIPLE BLIND
- #61: RANDOMIZED-CONTROLLED-TRIAL / all subheadings
- #62: explode CLINICAL-TRIAL / all subheadings
- #63: MAJOR-CLINICAL-STUDY / all subheadings
- #64: RANDOMIZATION / all subheadings
- #65: #50 or #53 or #60 or #61 or #62 or #63 or #64
- #66: #46 and #65