# Appendix D. Search Strategy: CINAHL for Observational Studies

- Set Search

- 001 ventilator weaning/
- 002 trial$ of spontaneous breathing.ti,ab.
- 003 exp respiration, artificial/
- 004 exp intubation, intratracheal/
- 005 patient triggered ventilation.ti,ab.
- 006 (intermittent manditory ventilation or simv or imv).ti,ab.
- 007 positive pressure ventilation.ti,ab.
- 008 pressure support ventilation.ti,ab.
- 009 nippv.ti,ab.
- 010 mechanical ventilation.ti,ab.
- 011 (continuous positive airway pressure or cpap).ti,ab.
- 012 bipap.ti,ab.
- 013 wean$.ti,ab.
- 014 extubat$.ti,ab.
- 015 duration.ti,ab.
- 016 discontinu$.ti,ab.
- 017 or/3-12
- 018 or/13-16
- 019 17 and 18
- 020 1 or 2 or 19
- 021 exp sensitivity/
- 022 exp diagnostic errors/
- 023 reproducibility of results/
- 024 (sensitivit: or specificit: or predictive value:).tw.
- 025 (false positive or false negative or false rate:).tw.
- 026 (likelihood ratio: or receiver operat: curve:).tw.
- 027 (pretest likelihood or pre test likelihood or posttest likel
- 028 (ppv or npv or roc or diagnostic standard: or accura:).tw.
- 029 (pretest probability or pre test probability or posttest pro
- 030 (predict: or index:).tw.
- 031 exp ventilation, mechanical/
- 032 18 and 31
- 033 32 or 20
- 034 false negative reactions/
- 035 false positive reactions/
- 036 exp clinical assessment tools/
- 037 (measurement issues and assessments).ti,sh,ab,it.
- 038 (reliability and validity).ti,sh,ab,it.
- 039 exp "reliability and validity"/
- 040 exp construct validity/
- 041 exp observer bias/
- 042 nursing assessment/
- 043 or/21-30
- 044 or/34-43
- 045 33 and 44
- 046 45