# Appendix C. Search Strategy: CINAHL for Intervention Studies

- Set Search

- 001 ventilator weaning/
- 002 trial$ of spontaneous breathing.ti,ab.
- 003 exp respiration, artificial/
- 004 exp intubation, intratracheal/
- 005 patient triggered ventilation.ti,ab.
- 006 (intermittent manditory ventilation or simv or imv).ti,ab.
- 007 positive pressure ventilation.ti,ab.
- 008 pressure support ventilation.ti,ab.
- 009 nippv.ti,ab.
- 010 mechanical ventilation.ti,ab.
- 011 (continuous positive airway pressure or cpap).ti,ab.
- 012 bipap.ti,ab.
- 013 wean$.ti,ab.
- 014 extubat$.ti,ab.
- 015 duration.ti,ab.
- 016 discontinu$.ti,ab.
- 017 or/3-12
- 018 or/13-16
- 019 17 and 18
- 020 1 or 2 or 19
- 021 exp ventilation, mechanical/
- 022 21 and 18
- 023 20 or 22
- 024 randomized controlled trial.pt.
- 025 controlled clinical trial.pt.
- 026 randomized controlled trials.sh.
- 027 random allocation.sh.
- 028 double-blind method.sh.
- 029 single-blind method.sh.
- 030 or/24-29
- 031 (animal not human).sh.
- 032 30 not 31
- 033 clinical trial.pt.
- 034 exp clinical trials/
- 035 (clin$ adj25 trial:).ti,ab.
- 036 ((single$ or doubl$ or trebl$ or tripl$) adj25 (blind$))
- 037 placebos.sh.
- 038 placebo$.ti,ab.
- 039 random$.ti,ab.
- 040 research design.sh.
- 041 or/33-40
- 042 41 not 31
- 043 42 not 32
- 044 comparative study.sh.
- 045 exp evaluation studies/
- 046 follow-up studies.sh.
- 047 prospective studies.sh.
- 048 (control$ or prospectiv$ or vounteer$).ti,ab.
- 049 or/44-48
- 050 49 not 31
- 051 50 not (32 or 43)
- 052 32 or 43 or 51
- 053 exp clinical trials/
- 054 exp clinical research/
- 055 random assignment/
- 056 research.pt.
- 057 30 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 45 or 47
- 058 57 and 23
- 059 58 not letter.pt.
- 060 59 not editorial.pt.
- 061 60