# Appendix L. Extraction Form for Observational Studies

## Data extraction for Observational Studies, page 1

[image]

## Data extraction for Observational Studies, page 2

[image]

## Data extraction for Observational Studies, page 3

[image]

## Data extraction for Observational Studies, page 4

[image]

## Data extraction for Observational Studies, page 5

[image]

## Data extraction for Observational Studies, page 6

[image]

## Data extraction for Observational Studies, page 7

[image]